# Appendix E Annotated Common Data Application

## Introduction

In pursuit of the Office of the Assistant Secretary for Planning and Evaluation’s goal of supporting efforts to develop better data resources and inform ongoing work within the U.S. Department of Health and Human Services, the states, and the health research community to build national all payer claims database (APCD) capacity to conduct patient-centered outcomes research, we have developed a prototype common application that could be used to apply for access to data from multiple state APCDs at once, addressing one barrier to research using multiple state APCDs under the status quo. To expedite researcher access to APCD data from multiple states, we developed this draft prototype by reviewing elements that appear in six existing state APCD data applications, the Healthcare Cost and Utilization Project purchase application for state databases, the Research Data Assistance Center’s (ResDAC’s) data application, and conversations with key stakeholders.

A remaining question to be discussed with states is how and where to submit such an application. One option is for researchers to submit one application to a central processor to obtain data from all participating states; another option is for all states to use the same application but not a central processor, necessitating that researchers complete one application but submit it to as many states’ APCDs as needed.

Annotations describing the context or rationale for items appear below relevant items in bold, red text.

### I Requester Information

1. Name:
2. Title:
3. Email address:
4. Phone number:
5. Shipping address:
6. Organization name and address:
7. Organization type (select one):
  a. Academic institution
  b. Research organization (not academic institution]
  c. Other nonprofit organization
  d. Health insurer
  e. Health care provider
  f. State agency
  g. Federal agency
  h. Trade association, lobbying group, consortium
  i. Independent consultant
  j. Pharmaceutical, biotechnology, medical product firm
  k. Other:

The contact information requested here was fairly uniform across the core states’ existing APCD data applications. Item 7 (Organization type) represents an amalgam of several items from different states’ applications. Some states may have different expectations or scrutiny of projected products based on the type of organization requesting data. Items 6 and 7 could potentially be used to identify conflicts of interest or data requests for commercial uses.

### II Project Information

8. Primary investigator (PI) name and title:
  a. PI qualifications: Describe previous experience using claims data. This question should be answered by the PI or project manager and should encompass the experience of the entire project team who will be using the data.
    Several states ask for PI qualifications, which may help administrators know whether data requestors may need technical assistance.
  b. Other users’names and titles:
9. Title of project:
10. Project start and end dates:
11. Describe your study background, objectives, aims, and purpose.
  Different states asked for a range of information related to the study. This may include a brief 150-word abstract or may include more-extensive explanation of project objectives, brief summary of the literature, specific research question(s), individual specific aims, project methodology, and description of intended products or reports to be derived from the requested data.
12. What is the purpose of your project (select one)?
  a. Research
  b. Health care operations
  c. Public health activities
  d. Other:
  Potential subcategories of this item that were used in some state applications include the following: assess utilization of health care services, observe cost trends, compare providers/health plans, create or enhance a commercial product or service, assess population health.
13. Provide an overview of your intended use of the data.
  a. Describe how the data will be beneficial to your project. Use quantitative indicators of public health importance where possible. For example: variation in costs of care; rates of underutilization or overutilization of service; health system performance measures; the effect of public health initiatives, health insurance, etc.
  b. Explain why the planned project could not be practicably conducted without access to and use of protected health information (PHI).
  c. Please describe your cohort and how it is the minimum necessary to achieve your research objectives. Include estimated cohort size.
14. Describe the intended product or report that will be derived from the requested data.
15. Do you anticipate that the results of your analysis will be published or made publicly available? If yes, how do you intend to disseminate the results of the study (e.g., publication in a professional journal, poster presentation, newsletter, webpage, seminar, conference, statistical tabulation, etc.)?
16. Describe your plans to use or otherwise disclose APCD data, or any data derived or extracted from such data, in any paper, report, website, statistical tabulation, seminar, or other setting that is not disseminated to the public.
  The information requested in items 13–16 was commonly covered across the core states’ APCD data applications.
17. Briefly explain why completing this project is in the public interest. Use quantitative indicators of public health importance where possible—for example, numbers of deaths or incident cases; age-adjusted, age-specific, or crude rates; or years of potential life lost. Uses that serve the public interest include but are not limited to health cost and utilization analysis to formulate public policy; studies that promote improvement in population health, health care quality or access; and health planning tied to evaluation or improvement of state or federal government initiatives.
  Several states ask some variation of this item. It is not clear how many (if any) use this question to screen out potential commercial uses of their data. If the purpose is to identify requests for data for commercial uses, a more direct question may be preferred.
18. Select the level of detail you are requesting:
  a. Standard de-identified dataset
  b. Limited dataset
  c. Identified dataset
  Not all states provide all three options, or anything besides a fully customized dataset. Some states do not have a standard limited dataset. Some states are limited legislatively in what level of detail they can release. Similarly, there is not a common definition of a standard de-identified dataset or a limited dataset. Given the purpose of this project, the items in this application generally assume that the requester is asking for potentially identifiable information.
19. Complete the Data Element Dictionary to identify the specific data elements that are required for this project, and attach it to this application. In keeping with the minimum necessary standard established under the Health Insurance Portability and Accountability Act (HIPAA), APCD policy is to release only those data elements that are required to complete your project. Please include a rationale for each data element requested.
  While many states do offer a limited dataset option, these generally do not include any potentially identifiable information and may be of limited use for researchers. For custom or research-level datasets, most states ask for individual data element selection, with justification for additional elements beyond what is included in any available limited dataset.

### III Data Privacy

20. Explain how your use of data will involve no more than a minimal risk to the privacy of individuals. As part of your response, please address how you will protect the data from improper use or disclosure and ensure that the data will not be reused or disclosed to any other person or entity, except as required by law, for authorized oversight of the research for which the data was requested, or for other research for which the use or disclosure of PHI would be permitted under 45 Code of Federal Regulations 164.512(i)(2)(ii). The response to this element should be brief and should not represent a comprehensive data security plan. Data security is addressed later in the application.
21. Please describe the techniques you will use to prevent re-identification when findings or outputs result in cell sizes less than 11 (e.g., aggregation, cell suppression, generalization, or perturbation).
  Most states did not include a distinct cell size in their re-identification prevention questions. Two states limited reporting of cell sizes less than 11, and one state limited reporting of cell sizes less than 30.
22. Do you intend to link or merge APCD data to other data?
  a. If yes, please indicate below the types of data to which APCD data will be linked:
    i. Individual patient-level data (e.g., disease registries, death data)
    ii. Individual provider-level data (e.g., American Medical Association Physician Masterfile)
    iii. Individual facility-level data (e.g., American Hospital Association data)
    iv. Aggregate data (e.g., Census data)
    v. Other (please describe):
  b. If yes, describe the dataset(s) to which the APCD data will be linked, indicate which APCD data elements will be linked, and specify the purpose for each linkage.
  c. For each proposed linkage above, please describe your method or selected algorithm (e.g., deterministic or probabilistic) for linking each dataset. If you intend to develop a unique algorithm, please describe how it will link each dataset.
  d. Attach or provide below a complete listing of the variables from all sources to be included in the final linked analytic file.
  e. Please identify the specific steps you will take to prevent the identification of individual patients in the linked dataset.
  About half of the applications reviewed asked about data linkages. This item is comprehensive to include the linkage information requested by those states. One state strongly prefers to conduct any data linkages in house prior to providing the dataset in order to prevent potential re-identification by linkage.
23. Has an institutional review board (IRB) reviewed your project?
  a. If yes, a copy of the approval letter and protocol must be included with the application package.
  b. No, this project is not human subject research and does not require IRB review.

### IV Data Security

24. Record-level or derivative data that can be re-identified must be destroyed within 30 days of the end of the data use agreement in a manner that renders it unusable, unreadable, or indecipherable. What are your plans for destruction of the dataset and any potentially identifiable elements of the data once the data use agreement has expired?
  Every state asked for some confirmation of data destruction plans.
25. Please complete and attach the Data Management Plan Self-Attestation Questionnaire (DMP SAQ) from ResDAC: https://resdac.org/request-form/dmp-saq
  The amount of information about data security plans requested by states varied widely. Some states were less strict, and some states were stricter. The DMP SAQ is extensive; it is 24 pages long and covers access controls, auditing and accountability, security assessments, incident response, media protection and security, physical and environmental controls, risk assessments, and privacy controls, among others. The ResDAC questionnaire is offered as a potential example because it is comprehensive and is already used to access state Medicaid data.