# Appendix D Common Data Application

## I Requester Information

1. Name:
2. Title:
3. Email address:
4. Phone number:
5. Shipping address:
6. Organization name and address:
7. Organization type (select one):
  a. Academic institution
  b. Research organization (not academic institution)
  c. Other nonprofit organization
  d. Health insurer
  e. Health care provider
  f. State agency
  g. Federal agency
  h. Trade association, lobbying group, consortium
  i. Independent consultant
  j. Pharmaceutical, biotechnology, medical product firm
  k. Other:

## II Project Information

8. Primary investigator (PI) name and title:
  a. PI qualifications: Describe previous experience using claims data. This question should be answered by the PI or project manager and should encompass the experience of the entire project team who will be using the data.
  b. Other users’ names and titles:
9. Title of project:
10. Project start and end dates:
11. Describe your study background, objectives, aims, and purpose.
12. What is the purpose of your project (select one)?
  a. Research
  b. Health care operations
  c. Public health activities
  d. Other:
13. Provide an overview of your intended use of the data.
  a. Describe how the data will be beneficial to your project. Use quantitative indicators of public health importance where possible. For example: variation in costs of care; rates of underutilization or overutilization of service; health system performance measures; the effect of public health initiatives, health insurance, etc.
  b. Explain why the planned project could not be practicably conducted without access to and use of protected health information (PHI).
  c. Please describe your cohort and how it is the minimum necessary to achieve your research objectives. Include estimated cohort size.
14. Describe the intended product or report that will be derived from the requested data.
15. Do you anticipate that the results of your analysis will be published or made publicly available? If yes, how do you intend to disseminate the results of the study (e.g., publication in a professional journal, poster presentation, newsletter, webpage, seminar, conference, statistical tabulation, etc.)?
16. Describe your plans to use or otherwise disclose all payer claims database (APCD) data, or any data derived or extracted from such data, in any paper, report, website, statistical tabulation, seminar, or other setting that is not disseminated to the public.
17. Briefly explain why completing this project is in the public interest. Use quantitative indicators of public health importance where possible—for example, numbers of deaths or incident cases; age-adjusted, age-specific, or crude rates; or years of potential life lost. Uses that serve the public interest include but are not limited to health cost and utilization analysis to formulate public policy; studies that promote improvement in population health, health care quality, or access; and health planning tied to evaluation or improvement of state or federal government initiatives.
18. Select the level of detail you are requesting:
  a. Standard de-identified dataset
  b. Limited dataset
  c. Identified dataset
19. Complete the Data Element Dictionary to identify the specific data elements that are required for this project, and attach it to this application. In keeping with the minimum necessary standard established under the Health Insurance Portability and Accountability Act (HIPAA), APCD policy is to release only those data elements that are required to complete your project. Please include a rationale for each data element requested.

## III Data Privacy

20. Explain how your use of data will involve no more than a minimal risk to the privacy of individuals. As part of your response, please address how you will protect the data from improper use or disclosure and ensure that the data will not be reused or disclosed to any other person or entity, except as required by law, for authorized oversight of the research for which the data was requested, or for other research for which the use or disclosure of PHI would be permitted under 45 Code of Federal Regulations 164.512(i)(2)(ii). The response to this element should be brief and should not represent a comprehensive data security plan. Data security is addressed later in the application.
21. Please describe the techniques you will use to prevent re-identification when findings or outputs result in cell sizes less than 11 (e.g., aggregation, cell suppression, generalization, or perturbation).
22. Do you intend to link or merge APCD data to other data?
  a. If yes, please indicate below the types of data to which APCD data will be linked:
    i. Individual patient-level data (e.g., disease registries, death data)
    ii. Individual provider-level data (e.g., American Medical Association Physician Masterfile)
    iii. Individual facility-level data (e.g., American Hospital Association data)
    iv. Aggregate data (e.g., Census data)
    v. Other (please describe):
  b. If yes, describe the dataset(s) to which the APCD data will be linked, indicate which APCD data elements will be linked, and specify the purpose for each linkage.
  c. For each proposed linkage above, please describe your method or selected algorithm (e.g., deterministic or probabilistic) for linking each dataset. If you intend to develop a unique algorithm, please describe how it will link each dataset.
  d. Attach or provide below a complete listing of the variables from all sources to be included in the final linked analytic file.
  e. Please identify the specific steps you will take to prevent the identification of individual patients in the linked dataset.
23. Has an institutional review board (IRB) reviewed your project?
  a. If yes, a copy of the approval letter and protocol must be included with the application package.
  b. No, this project is not human subject research and does not require IRB review.

## IV Data Security

24. Record-level or derivative data that can be re-identified must be destroyed within 30 days of the end of the data use agreement, in a manner that renders it unusable, unreadable, or indecipherable. What are your plans for destruction of the dataset and any potentially identifiable elements of the data once the data use agreement has expired?
25. Please complete and attach the Data Management Plan Self-Attestation Questionnaire (DMP SAQ) from the Research Data Assistance Center: https://resdac.org/request-form/dmp-saq