# Appendix C Use Case 2: Total Costs for Individuals with Long COVID

## Purpose

The purpose of this use case is to provide guidance for estimating the average total cost of care for a person who has long COVID in 2022 using one or more state APCDs. We specify how to identify a cohort of individuals with long COVID during 2022 and, for more advanced users, offer considerations for how to identify a comparison group of similar individuals without long COVID. We then provide guidance on calculating and comparing health care costs for both groups. This use case is not intended to provide step-by-step directions for someone new to working with APCD data, but rather to be used as a starting point for individuals interested in understanding how APCDs may be used to study long COVID costs.

## Background and Motivation

It is estimated that 10 to 40 percent of people infected with COVID-19 develop long COVID (Chen et al., 2022; Cutler, 2022; Logue et al., 2021; Thompson et al., 2022). Long COVID is typically diagnosed 30 to 60 days following a COVID-19 infection and may include respiratory and heart symptoms (e.g., cough and chest pain), neurological symptoms (e.g., headache and brain fog), and fatigue, among other symptoms, that may last weeks, months, or years (U.S. Centers for Disease Control and Prevention, 2022). Understanding the health care costs associated with long COVID is important because of the significant implications of long COVID for health care systems, insurers, and individuals. Furthermore, promoting the use of APCDs for studying long COVID is important for advancing patient-centered outcomes research. Due to the ability to conduct longitudinal analyses using state APCDs, these datasets may offer opportunities for comparing the effectiveness of different interventions for treating long COVID and calculating OOP spending for individuals with long COVID.

## Value of Using APCDs to Examine This Topic

Because many APCDs allow researchers to follow unique individuals over time and across settings of care, APCDs offer an opportunity to study health care costs associated with long COVID. APCDs are well suited for this type of study because many allow for the study of individuals as they churn across different types of insurance over time, which enables a lengthy period of follow-up post-diagnosis. For example, a report from Colorado released in December 2022 used the Colorado APCD to examine the number of Coloradans diagnosed with long COVID, finding that women were more likely to experience long COVID than men (Colorado Office of Saving People Money on Health Care, 2022).

Furthermore, APCDs provide detailed information about prices paid for health care services by insurers and patients. Detailed price information in APCDs has been used to examine variation in prices for COVID-19 testing (Colorado Center for Improving Value in Health Care, 2023), variation in primary care across types of health insurance (Oregon Health Authority, 2022), and variation in prices across health plans (Whaley et al., 2020). Thus, APCDs can offer important insights into patient and insurer payments related to long COVID.

## Data and Sample Construction

This analysis requires information from eligibility files (e.g., dates of enrollment in medical insurance and the type of insurance [e.g., Medicaid, Medicare, private insurance]), medical claims files (e.g., diagnosis codes, payment amounts), and pharmacy claims files (e.g., payment amounts). It assumes the availability of a longitudinal person identifier that can be used to link multiple eligibility and claims records belonging to the same individual over time and across settings of care. Table C.1 provides information about the files and data elements used in this analysis, based on the APCD-CDL^™^ from the APCD Council, the National Association of Health Data Organizations, and the University of New Hampshire (APCD Council, National Association of Health Data Organizations, and the University of New Hampshire, 2021).

Costs will be generated using 2022 data. Because the International Classification of Diseases, Tenth Revision (ICD-10) code for post-acute sequelae of COVID-19 (i.e., long COVID) was introduced in October 2021, a study period of October 2021 through the end of December 2022 is recommended to ensure that diagnoses of long COVID are not missed during 2022.

Using eligibility files, a sample limited to individuals continuously enrolled in medical insurance during this period should be identified. To ensure that costs can be calculated consistently, the sample should be limited to individuals with the same type of insurance coverage during this period. The span of insurance enrollment can be identified based on the plan effective date and plan term date, with the insurance type identified using the member insurance/product category code. We suggest focusing on individuals aged 18 years and older because long COVID may present differently or be diagnosed differently in children. The resulting eligibility file should be constructed at the person-month level, so that everyone has 15 rows spanning October 2021 through December 2023. As described in Table C.1, the eligibility file will be used to obtain information on gender,^6^ race, ethnicity, and insurance type. In addition, a unique member identifier will be used to link records in the eligibility file to the medical claims and pharmacy claims.

Table C.1 List of Variables Needed to Construct Analytic File

APCD-CDL^™^ Data Element # | Data Element Name | Description | Derived From
CDLME016 | SSID or Member ID | Unique identifier used to follow individuals over time across care settings and across insurers | Eligibility file
CDLME040 | Primary Insurance Indicator | Insurance Type/Product Code | Eligibility file
CDLME004 | Member Insurance/Product Category code | Use categories from eligibility file | Eligibility file
CDLME050 | Plan Effective Date | Date eligibility started for this member under this plan type | Eligibility file
CDLME051 | Plan Term Date | Last continuous day of coverage (date eligibility ended) for this member under this plan | Eligibility file
CDLME018 | Sex or Gender | Use categories from eligibility file | Eligibility file
CDLME019 | Date of Birth | N/A | Eligibility file
CDLME029 | Race | Use categories from eligibility file | Eligibility file
CDLME032 | Hispanic Ethnicity | Use categories from eligibility file | Eligibility file
CDLMC007 | Version Number | Begins with 0 and is incremented by 1 for each subsequent version of the claim | Medical claims
CDLMC160 | Claim Line Type | Report the code that defines the claim line status in terms of adjudication. Valid codes are: O=Original; V=Void; R=Replacement; B=Back Out; A=Amendment; D=Denial. | Medical claims
CDLMC119 | Date of Service – From | CCYYMMDD. First date of service for this service line. | Medical claims
CDLMC120 | Date of Service – Thru | CCYYMMDD Last date of service for this service line. | Medical claims
CDLMC033 | Place of Service | N/A | Medical claims
CDLMC037 | Principal Diagnosis | N/A | Medical claims
CDLMC038–CDLMC062 | Other Diagnosis, 1–24 | N/A | Medical claims
CDLMC125 | Plan Paid Amount | Includes all health plan payments and excludes all member payments | Medical claims
CDLMC131 | Allowed Amount | Maximum amount contractually allowed | Medical claims
CDLMC126 | Co-Pay Amount | Co-payment dollar amount paid for which the individual is responsible | Medical claims
CDLMC127 | Coinsurance Amount | The dollar amount of coinsurance for this claim line paid. | Medical claims
CDLMC128 | Deductible Amount | The dollar amount for this claim line applied to the deductible. | Medical claims
CDLPC007 | Version number | begins with 0 and is incremented by 1 for each subsequent version of the claim | Pharmacy claims
CDLPC066 | Claim Line Type | Report the code that defines the claim line status in terms of adjudication. Valid codes are: O=Original; V=Void; R=Replacement; B=Back Out; A=Amendment; D=Denial. | Pharmacy claims
CDLPC023 | Date Prescription Filled | N/A | Pharmacy claims
CDLPC037 | Plan Paid Amount | Includes all health plan payments and excludes all member payments | Pharmacy claims
CDLPC038 | Allowed Amount | Maximum amount contractually allowed | Pharmacy claims
CDLPC043 | Co-Pay Amount | Co-payment dollar amount paid for which the individual is responsible | Pharmacy claims
CDLPC044 | Coinsurance Amount | The dollar amount of coinsurance for this claim line paid. | Pharmacy claims
CDLPC045 | Deductible Amount | The dollar amount for this claim line applied to the deductible. | Pharmacy claims
CDLPC048 | Member Self-Pay Amount | Amount paid by member in addition to those listed in CDLPC043, CDLPC044, CDLPC045 | Pharmacy claim

NOTE: SSID = Social Security ID.

### Considerations for When Additional Data Are Available

Ideally data through the end of 2023 would be extracted to allow a 12-month follow-up period for all individuals with a diagnosis date in 2022. At the time of writing this report, 2023 had not yet ended; thus, we have proposed an approach using the most recent data available. We encourage using data through the end of 2023 and beyond when available. This would allow for a full year of follow-up on all individuals diagnosed with long COVID, as individuals with later diagnosis dates may have different treatment patterns in the early months of their diagnoses.

## Identifying Individuals with Long COVID

Individuals with long COVID will be identified using ICD-10 code U09.9. This diagnosis code does not have to be observed as a primary diagnosis for an individual to be considered as having long COVID. Individuals will be identified as having long COVID when ICD-10 code U09.9 is observed in their medical claims during the study period. The definition of long COVID is likely to evolve over time. These specifications are written assuming that long COVID is an absorbing state (i.e., once an individual is diagnosed with long COVID, they always have long COVID). Users of these specifications should consider whether this definition remains appropriate at the time of their analysis.

To ensure that we are identifying an individual’s initial long COVID diagnosis, we will look back to October 2021 when the long COVID diagnosis was first introduced. Table C.2 shows examples of how observation periods are calculated for each individual.

- For individual #1, their first long COVID diagnosis is observed in February 2022. Thus, the observation period for individual #1 spans February 2022 through the end of December 2022 (11 months).
- For individual #2, their initial long COVID diagnosis is observed in November 2021. Because costs will be calculated in 2022, the observation period for individual #2 spans January 2022 through the end of December 2022 (12 months).
- For individual #3, their initial long COVID diagnosis is observed in March 2022. Thus, the observation period for individual #3 spans March 2022 through the end of December 2022 (10 months).

Table C.2 Illustration of Look-Back and Follow-Up Period for Identifying a Long COVID Case

Year | 2021 | | | 2022
Month | O | N | D | J | F | M | A | M | J | J | A | S | O | N | D
Person 1 | | | | | L* | L | L | | | | L | L | L
Person 2 | | L* | | | | | L | L | L | | | | L | L | L
Person 3 | | | | | | L* | L | L | | L | L | | | L

NOTE: Gray shading indicates the months included in the observation period for each person. L* indicates when the first long COVID diagnosis was observed. L indicates when long COVID diagnoses were observed in an individual’s medical claims.

### Additional Considerations and Future Directions for Identifying Long COVID

The World Health Organization defines an individual as having long COVID if they have at least two new-onset persistent symptoms lasting for 60 days after a COVID-19 infection. The U.S. Centers for Disease Control and Prevention defines an individual as having long COVID if they have at least one new-onset persistent symptom lasting for 30 days after a COVID-19 infection. In states with a linkage to an HIE or state laboratory testing data, it may be possible to identify total costs of long COVID dating back to the initial positive COVID-19 lab test result. This could improve the interpretability of the study by potentially isolating new-onset long COVID cases as well as allow a look at the initial COVID costs prior to a long COVID diagnosis. Implementing these specifications using linked APCD and HIE data, however, is out of scope of the analysis described in this use case.

## Identifying a Comparison Group

In addition to calculating health care costs for individuals with long COVID, it may also be interesting to compare total annual health care costs for individuals with and without long COVID in order to understand the magnitude of costs that may be associated with long COVID. Long COVID incidence may be associated with factors (e.g., age and gender) that may also predict utilization and spending. We caution that the best approach for identifying an appropriate comparison group will likely vary based on the dataset and as the definition of long COVID evolves.

To provide a benchmark for spending that is relevant for long COVID patients, we will calculate a weighted average total cost of care for a sample of patients that match the long COVID patients on

- age
- gender
- insurance coverage type (defined using guidance from Carman and Dworsky [2020]):
  – Medicare
  – Medicaid
  – ESI
  – Marketplace coverage
  – other nongroup coverage.

The use of a within-payer and within-state comparison group will allow the calculation of total costs of care for long COVID patients as dollar and percentage differences from similar patients without long COVID, facilitating comparison of long COVID cost impacts across states and payers with differing demographics and health care prices.

### Considerations for a Comparison Group

Depending on the goals of the analysis and data availability, different comparison groups could be considered.

- Health care utilizers: By definition, the group of individuals with long COVID will have health care utilization, but the comparison group may not. Thus, the comparison group would mechanically have lower costs than the long COVID group. Because emerging research suggests that individuals with chronic health conditions may be more likely to develop long COVID (Subramanian et al., 2022), it may be of interest to construct a comparison group of "health care utilizers" to compare how costs differ for individuals with long COVID and individuals who have used health care in the study period. To do so, individuals in the comparison group could be required to have at least one bill for medical care during the study period and could potentially be matched to long COVID patients on the basis of an index date or initial utilization event of a similar type.
- Individuals hospitalized with COVID: In addition, individuals who were hospitalized with COVID but did not progress to long COVID may also provide an alternative comparison group. Moreover, because individuals with chronic conditions may be at higher risk of long COVID or experience more complications due to long COVID, it may also be of interest to make comparisons among individuals with chronic conditions with and without long COVID.
- Individuals with and without COVID: In states with a linkage to an HIE or state laboratory testing data, it may be possible to construct comparison groups of individuals with (1) long COVID, (2) a prior COVID diagnosis and no long COVID diagnosis, and (3) no long COVID or COVID diagnosis. However, because individuals with mild cases of COVID may not interact with the health systems, these data may not be an appropriate way to identify cases of COVID.

Because data-use agreements typically require that small cell sizes (i.e., <11) are not publicly reported, consideration should be paid to the sample sizes of the comparison group and the group with long COVID, overall and among subgroups.

## Estimating Health Care Costs

Costs will be estimated overall and specific to long COVID in each month of 2022. Costs will be estimated using final-action, paid claims. Costs of interest include the following:

- Paid amount: the amount paid to a health care provider per episode by the health plan or employer
- Patient payment: the OOP amount paid by a patient, which can be calculated by summing the deductible, copayment, and coinsurance payment
- Allowed amount: the amount paid to a health care provider per episode, including amounts paid by the health plan and any amounts due from the patient, such as deductibles, copayments, and coinsurance. The allowed amount should be the sum of patient payment and the paid amount.

The specific variable names for these cost variables in the medical claims and pharmacy claims files are listed in Table C.1. To estimate costs specific to long COVID using medical claims, we can sum costs over two sets of claims:

- Sum payments on claim lines that have a primary diagnosis of long COVID in each month (narrower measure of long-COVID-related costs).
- Sum payments on claim lines that have any diagnosis of long COVID in each month (broader measure of long-COVID-related costs).

If a claim spans multiple months (e.g., enters hospital on 01/29/2022 and leaves hospital on 02/05/2022), the costs should be assigned to the month based on when the service was completed (i.e., using the end-of-service date).

Pharmacy claims do not have diagnosis codes, limiting our ability to identify prescriptions written specifically for long COVID. Thus, pharmacy claims will be excluded in calculations of long COVID-specific costs. However, it may be possible to estimate drug spending associated with long COVID by linking medical claims with long COVID diagnoses to pharmacy claims by member ID and date. This linkage would identify prescriptions occurring on the same date as a visit with a long COVID diagnosis. While this may lead to misclassifying some prescriptions as related to long COVID, this could be considered an upper bound of an estimate of drug spending associated with long COVID.

To estimate total costs for individuals in the long COVID and comparison groups, using medical and pharmacy claims:

- Sum payments on all medical claim lines for individuals.
- Sum payments on all pharmacy claim lines for individuals.

When summing these payments for individuals with long COVID, all costs should be included in all months—regardless of whether a diagnosis for long COVID is observed at that time.

It may be of interest to compare costs by place of service (e.g., office versus hospital). This could be accomplished by using the place-of-service variable as follows:

- Office = 11,17, 50, 71, 72
- Inpatient hospital = 21
- ED = 23
- Urgent care facility = 20.

Because the place-of-service variable may be missing for some claims, additional information may be used to identify the place of service. For example, ED visits can also be identified using revenue center codes (0450–0459 or 0981) and Healthcare Common Procedure Coding System codes (99281, 99282, 99283, 99284, 99285).

Costs will be generated at the level of the person-month. These costs will be averaged for each group (those with and without long COVID) and multiplied by 12 to generate estimated annual costs. In addition to estimating average costs, we also suggest examining costs at the 25th, 50th, and 75th percentiles to illustrate a range of costs incurred. Some individuals with long COVID may be observed in 2022 prior to their diagnosis of long COVID. These months will not be used to calculate average costs for patients with or without long COVID.

### Examining Costs Across Subgroups

As illustrated in Table C.3, we suggest examining costs separately by insurance type and within insurance type reporting costs by age group, gender, and race/ethnicity.

Table C.3 Example Table Illustrating Total Costs by Subgroups Among Individuals With and Without Long COVID

Subgroup | Among People With Long COVID | Among People Without Long COVID
Commercial insurance (can report by type: ESI, Marketplace, other nongroup)
By gender
By age group
By race/ethnicity
Medicare Advantage
By gender
By age group
By race/ethnicity
Medicare FFS
By gender
By age group
By race/ethnicity
Medicaid
By gender
By age group
By race/ethnicity

## Multi-State Applications

These specifications can be applied to the analysis of one or more state APCDs. Using data from multiple state APCDs has the potential to improve this analysis. First, these specifications could be used to compare average costs across states. Second, if analyzing data from a single state, there may not be sufficient numbers to generate estimates of small subgroups (e.g., within age, gender, and race). Pooling data across multiple states may allow for the exploration of costs in these small subgroups. Third, this analysis would be strengthened if the analysis were able to follow people who move across states or track care obtained in states different from an individual’s home state. While this is not yet the norm, a multi-state APCD that links individual records across states could make this possible. Fourth, using data from multiple states could allow for the examination of the impact of different state policies. These specifications could be extended to examine the impact of different state policies on coverage of COVID treatment and examine whether those are related to rates of long COVID diagnoses and costs. That said, analyses using more than one state APCD should be approached with care, as they require understanding the similarities and differences of APCDs across states, including the populations included (e.g., varying shares of ERISA plan reporting) and the file layouts (e.g., using the APCD-CDL^™^).

## Anticipated Challenges and Strategies for Addressing Them

Long COVID is defined by a time to presentation and therefore requires an index date. Ideally the index date would be an initial infection date, but that is likely to be challenging to determine using claims data due to the use of at-home testing or no testing at all. Therefore, we use the first appearance of U09.9 to identify individuals with long COVID. Moreover, in some cases, long COVID may be viewed as a "diagnosis of exclusion," where the diagnosis is only given if other diagnoses are first ruled out. Thus, observing an initial diagnosis date is unlikely to be synonymous with the start date of the condition.

Because long COVID is a relatively new condition, some long COVID diagnoses may be missed by clinicians, and thus misdiagnosed or undiagnosed individuals would not be accurately identified. This potential challenge may lessen over time as consensus grows regarding the diagnosis of long COVID. In addition, given the myriad of symptoms ascribed to long COVID, it may be challenging to examine costs specific to long COVID, which relies on clinicians to include a long COVID diagnosis when billing. Thus, comparing total costs for individuals with and without long COVID may be the preferred comparison for now.

One concern with APCD data is the potential lack of external validity because not all insurers submit data to APCDs. Another threat to external validity is that these specifications are focused on individuals who are continuously enrolled in the same type of insurance (e.g., commercial insurance, Medicaid, Medicare FFS, Medicare Advantage) for the duration of the study period, and thus costs may be different for individuals who churn across types of insurance during this time period. Moreover, the populations included in APCD data may vary across states (e.g., the share of ERISA plans submitting to APCDs varies).

## Considerations for Interpretation of Results

The definition of long COVID is likely to evolve over time. These specifications are written assuming that long COVID is an absorbing state (i.e., once an individual is diagnosed with long COVID, they always have long COVID). Users of these specifications should consider whether this definition remains appropriate at the time of their analysis.

Finally, these specifications are not intended to be used to provide estimates of the incidence or prevalence of long COVID. APCDs are unlikely to provide an accurate estimate of the incidence or prevalence of long COVID because these datasets do not include information on uninsured populations and because not all insured populations are included in APCDs. For example, APCDs have limited information from ERISA plans and from the FEHB program.

6 States vary in whether sex or gender is collected; the CDL uses a field for sex.