# Appendix B Use Case 1: Out-of-Pocket Spending on Insulin and Total Costs of Care for Insulin Users

## Purpose

The purpose of this use case is to provide guidance for examining OOP spending on insulin, as well as overall OOP spending and the total cost of care (including medical spending), for diabetes patients who use insulin ("insulin users"), using one or more state APCDs. This use case is not intended to provide step-by-step directions for someone new to working with APCD data, and some necessary details, such as code lists, are omitted. Rather, this use case is intended to be used as a starting point for individuals interested in understanding how APCDs may be used.

### Research Questions

The specifications presented in this document can be used to explore several questions, including the following:

1. What is the average OOP price paid for a 30-day supply of insulin?
2. What is the yearly OOP cost for insulin users associated with utilization of
  a. insulins?
  b. all diabetes drugs?
  c. all prescription drugs?
  d. total OOP costs (medical + prescription)?
3. What is the yearly total spending (OOP + plan paid amounts) for
  e. all prescription drugs?
  f. total cost of care (medical + pharmacy)?

## Background and Motivation

Insulin prices have risen in recent decades, and affordability challenges are now widespread even among patients with health insurance. Besides patient financial burden, high OOP costs for insulin are a concern because they are associated with worse adherence and higher rates of preventable hospitalizations and emergency department (ED) visits. OOP spending on insulin is therefore a timely example of economic burden as a key patient outcome, as defined in the 2019 reauthorization of OS-PCORTF (ASPE, 2022).

Not all insured patients are exposed to high OOP costs for insulin, and average OOP spending on insulin for commercially insured patients has risen much less than list prices and total payments (Laxy et al., 2021). However, high OOP costs are widespread among commercially insured patients with high-deductible health plans (HDHPs) or coinsurance-based cost-sharing, as well as among Medicare beneficiaries with Part D coverage (Cefalu et al., 2018). Paying for insulin can also be a major financial burden for lower-income patients across many insurance types.

## Value of Using APCDs to Study Insulin OOP Spending

Much of the existing evidence on insulin affordability challenges and their consequences either uses nationwide data that do not readily allow state-level analysis or is limited to the Medicare beneficiary population.^2^ State APCDs could be used to provide state-specific and substate estimates of the extent of insulin affordability challenges and how their prevalence varies across and within payers. The inclusion in APCDs of medical and pharmacy claims also makes them well suited for analyses describing insulin users’ OOP spending and total spending (including amounts paid by health plans) on prescription drugs and medical care more broadly.

In comparison to other data sources (such as household surveys and other public or private claims datasets), state APCD data offer several advantages for studying insulin OOP costs. These include

- inclusion of multiple payers and coverage types from both public and private insurance sources, allowing comparison of OOP spending across coverage types
- inclusion of medical and pharmacy claims for the same individuals, allowing measurement of total costs of care (in contrast to datasets that contain only pharmacy claims)
- the possibility of state-specific estimates with APCD data (with limitations noted below), which are not feasible with all health care datasets
- earlier availability of APCD data with a shorter data lag than household survey data or some commercial claims datasets (although data lags vary widely between states, and not all APCDs have shorter data lags than other data sources).

Insulin affordability has also been a priority of state and federal policymakers in recent years, leading to a number of policy changes and voluntary efforts by the private sector to decrease costs. Examples in Medicare include the Part D Senior Savings Model Test (which began in 2021) and selected provisions of the Inflation Reduction Act (effective in 2023). Voluntary actions by Eli Lilly and other insulin manufacturers are also intended to reduce list prices and limit OOP spending for privately insured patients. State initiatives, including in some states with well-developed APCDs (e.g., Colorado, Utah, Minnesota, and Washington), have also required benefit design changes that limit OOP costs for insulin.^3^

While the specifications described here do not propose a rigorous evaluation of these policy changes, evidence on insulin OOP spending over time may be of value to policymakers interested in whether the problems that have motivated these policy responses remain widespread or have been begun to show signs of improvement. Methods proposed here for using APCD data to measure insulin OOP spending could be used to evaluate some of these interventions in future work. Furthermore, pooling data from multiple states could allow some innovative extensions to the proposed study design, including the definition of a comparison group for statewide policy interventions.

## Data and Sample Construction

This analysis will focus on the population of insulin users observed in an APCD, defined as enrollees who fill at least one insulin prescription during a calendar year in the study period. We propose defining two different study populations.

An initial set of analyses (focused on the OOP price for a 30-day supply) will include all insulin prescriptions observed in the APCD, including those filled by patients who have insurance transitions or who are not observed in all months. Estimates of the price per prescription for this sample will address the question "What is the average OOP price paid for insulin among insulin users observed in the APCD?"

However, analysis focused on annual medical and prescription drug spending for insulin users may be difficult to interpret if individuals with part-year coverage or who have insurance transitions during the year are included in the sample. Annual spending measures for those with part-year coverage (i.e., who are unobserved in some months of the year) might be difficult to interpret due to deductibles and other nonlinear features of benefit design, while spending measures for those who are covered for the whole year but switch coverage types or payers will reflect variation in prices and benefit design across insurance plans. We note that OOP costs among those experiencing insurance transitions may also be of interest, but we do not propose an approach to examine this group here.

Analyses addressing our second and third research questions, which focus on annual OOP spending and total costs, will therefore restrict attention to insulin users who have a full year of continuous coverage with the same insurance plan.

### Key Measures and Data Elements Needed

This analysis will require numerous variables submitted in the eligibility, medical claims, and pharmacy claims files. Table B.1 provides a list of APCD data elements needed for the proposed analysis, drawing from data elements listed in the APCD-CDL^™^ produced by the APCD Council, the National Association of Health Data Organizations, and the University of New Hampshire (APCD Council, National Association of Health Data Organizations, and the University of New Hampshire, 2020).

Table B.1 Common Data Layout Data Elements Required for Insulin Use Case

APCD-CDL^™^ Data Element # | Data Element Name | Needed to Construct: | File
CDLMC002 | Payer Code | Linking Files Within Payers and Plans | Medical
CDLMC003 | Plan ID | Linking Files Within Payers and Plans | Medical
CDLMC005 | Payer Claim Control Number | Identifying/Processing Final Medical Claims | Medical
CDLMC006 | Line Counter | Identifying/Processing Final Medical Claims | Medical
CDLMC007 | Version Number | Identifying/Processing Final Medical Claims | Medical
CDLMC008 | Cross Reference Claims ID | Identifying/Processing Final Medical Claims | Medical
CDLMC032 | Type of Bill – Institutional | Medical OOP, Total Cost of Care | Medical
CDLMC087 | Revenue Code | Medical OOP, Total Cost of Care | Medical
CDLMC119 | Date of Service – From | Medical OOP, Total Cost of Care | Medical
CDLMC120 | Date of Service – Thru | Medical OOP, Total Cost of Care | Medical
CDLMC121 | Service Units – Quantity | Medical OOP, Total Cost of Care | Medical
CDLMC122 | Unit of Measure | Medical OOP, Total Cost of Care | Medical
CDLMC125 | Plan Paid Amount | Total Cost of Care | Medical
CDLMC126 | Co-Pay Amount | Medical OOP, Total Cost of Care | Medical
CDLMC127 | Coinsurance Amount | Medical OOP, Total Cost of Care | Medical
CDLMC128 | Deductible Amount | Medical OOP, Total Cost of Care | Medical
CDLMC129 | Other Insurance Paid Amount | Medical OOP, Total Cost of Care | Medical
CDLMC130 | COB/TPL Amount | Medical OOP, Total Cost of Care | Medical
CDLMC131 | Allowed Amount | Medical OOP, Total Cost of Care | Medical
CDLMC133 | Drug Code | Insulin OOP (for Insulin Pumps) | Medical
CDLMC156 | Type of Claim | Hospital Utilization | Medical
CDLMC157 | Claim Status | Medical OOP, Total Cost of Care | Medical
CDLMC158 | Denied Claim Line Indicator | Medical OOP, Total Cost of Care | Medical
CDLMC159 | Claim Adjustment Reason Code | Medical OOP, Total Cost of Care | Medical
CDLMC160 | Claim Line Type | Medical OOP, Total Cost of Care | Medical
CDLME002 | Payer Code | Plan Type | Eligibility
CDLME002 | Payer Code | Linking Files Within Payers and Plans | Eligibility
CDLME003 | Plan ID | Linking Files Within Payers and Plans | Eligibility
CDLME004 | Member Insurance Product/Category Code | Plan Type | Eligibility
CDLME005 | Start Year of Submission | Coverage Indicator (Identify Population of Interest) | Eligibility
CDLME006 | Start Month of Submission | Coverage Indicator (Identify Population of Interest) | Eligibility
CDLME007 | Insured Group or Policy Number | Linking Files Within Payers and Plans | Eligibility
CDLME018 | Member Gender | Demographics (Gender) | Eligibility
CDLME019 | Member Date of Birth | Demographics (Age) | Eligibility
CDLME026 | Member ZIP Code | Substate Geography | Eligibility
CDLME027 | Member FIPS County Code | Substate Geography | Eligibility
CDLME029 | Race 1 | Demographics (Race) | Eligibility
CDLME030 | Race 2 | Demographics (Race) | Eligibility
CDLME032 | Hispanic Indicator | Demographics (Ethnicity) | Eligibility
CDLME033 | Ethnicity 1 | Demographics (Ethnicity) | Eligibility
CDLME036 | Medical Coverage Under This Plan | Plan Type | Eligibility
CDLME037 | Pharmacy Coverage Under This Plan | Plan Type | Eligibility
CDLME040 | Primary Insurance Indicator | Plan Type | Eligibility
CDLME041 | Coverage Type | Plan Type | Eligibility
CDLME043 | Market Category Code | Plan Type | Eligibility
CDLME064 | HDHP Indicator | Plan Type | Eligibility
CDLPC002 | Payer Code | Linking Files Within Payers and Plans | Pharmacy
CDLPC003 | Plan ID | Linking Files Within Payers and Plans | Pharmacy
CDLPC005 | Payer Claim Control Number | Identifying/Processing Final Pharmacy Claims | Pharmacy
CDLPC006 | Line Counter | Identifying/Processing Final Pharmacy Claims | Pharmacy
CDLPC007 | Version Number | Identifying/Processing Final Pharmacy Claims | Pharmacy
CDLPC008 | Cross Reference Claims ID | Identifying/Processing Final Pharmacy Claims | Pharmacy
CDLPC009 | Insured Group or Policy Number | Linking Files Within Payers and Plans | Pharmacy
CDLPC023 | Date Prescription Filled | Identifying/Processing Final Pharmacy Claims | Pharmacy
CDLPC025 | Drug Code | Insulin Type | Pharmacy
CDLPC032 | Quantity Dispensed | Pharmacy OOP | Pharmacy
CDLPC033 | Days’ Supply | Pharmacy OOP | Pharmacy
CDLPC034 | Drug Unit of Measure | Pharmacy OOP | Pharmacy
CDLPC035 | Prescription Number | Pharmacy OOP | Pharmacy
CDLPC037 | Plan Paid Amount | Pharmacy OOP, Total Cost of Care | Pharmacy
CDLPC038 | Allowed Amount | Pharmacy OOP | Pharmacy
CDLPC039 | Sales Tax Amount | Pharmacy OOP | Pharmacy
CDLPC040 | Ingredient Cost/List Price | Pharmacy OOP, Total Cost of Care | Pharmacy
CDLPC041 | Postage Amount Claimed | Pharmacy OOP, Total Cost of Care | Pharmacy
CDLPC042 | Dispensing Fee | Pharmacy OOP, Total Cost of Care | Pharmacy
CDLPC043 | Co-Pay Amount | Pharmacy OOP, Total Cost of Care | Pharmacy
CDLPC044 | Coinsurance Amount | Pharmacy OOP, Total Cost of Care | Pharmacy
CDLPC045 | Deductible Amount | Pharmacy OOP, Total Cost of Care | Pharmacy
CDLPC046 | COB/TPL Amount | Pharmacy OOP, Total Cost of Care | Pharmacy
CDLPC047 | Other Insurance Paid Amount | Pharmacy OOP, Total Cost of Care | Pharmacy
CDLPC048 | Member Self-Pay Amount | Pharmacy OOP, Total Cost of Care | Pharmacy
CDLPC049 | Payment Arrangement Type Flag | Pharmacy OOP, Total Cost of Care | Pharmacy
CDLPC065 | Record Status Code | Identifying/Processing Final Pharmacy Claims | Pharmacy
CDLPC066 | Claim Line Type | Identifying/Processing Final Pharmacy Claims | Pharmacy
N.A. (not in CDL) | Longitudinal ID | Linking Files Across Payers and Over Time | Eligibility, Medical, Pharmacy

NOTE: COB/TPL = coordination of benefits and third-party liability; FIPS = Federal Information Processing Standards.

We also assume the availability of a longitudinal person ID that can be used to link multiple public and private eligibility and claims records belonging to the same individual across payers (e.g., pharmacy and medical coverage, Medigap and Medicare fee-for-service [FFS] coverage).

### Measuring Out-of-Pocket Spending and Total Spending on Prescription Drugs

A patient’s OOP liability (patient payment amount) on a prescription can be measured as the sum of deductible, copay, and coinsurance amounts, which are reported in APCD pharmacy claims files.

Variables needed:

- deductible amount
- copay amount
- coinsurance amount
- plan paid amount.

Additional pharmacy file variables may also be needed to de-duplicate claims, to select final status claims (in some APCDs), and to link pharmacy files to member eligibility records and medical claims (see Table B.1).

#### Classifying Prescriptions, Measuring Insulin Supply, and Identifying Insulin Users

The OOP cost measure of primary interest will be the normalized OOP price per 30 days’ insulin supply paid by insulin users in a calendar year, defined as in Laxy et al. (2021). The annual OOP measures that sum OOP costs over all prescriptions filled in a year for different sets of prescriptions, including insulins, all diabetes drugs, and all drugs, can also be calculated.

In addition to the cost-related variables listed above, construction of these measures will require variables appearing in APCD pharmacy claims files.

Variables needed:

- drug code (NDC)
- days’ supply
- date prescription filled.

Days’ supply as reported on the pharmacy claim can be used to construct a measure of OOP prices that is standardized to reflect the average price for a 30-day supply, following methods used in Laxy et al. (2021). This measure allows calculation of estimates of average OOP prices that include individuals with part-year coverage or who initiate (or cease) insulin use during a coverage year.

For a subset of patients with full-year coverage, annual prescription drug OOP cost measures can be calculated for different sets of prescription claims:

1. insulins (all insulins)
2. insulins by type (e.g., rapid-acting, short-acting, intermediate-acting, long-acting, mixed, combination, concentrate)
3. diabetes drugs
4. all prescriptions.

Crosswalks from Medispan can be used to assign insulin type based on the NDC, following the taxonomy of insulin types used in RAND’s evaluation of the Part D Senior Savings Model Test (Taylor et al., 2022). Identification of additional diabetes drugs can be done using RxNorm. (Medispan is a commercial product that must be licensed, while RxNorm is a publicly available database maintained by the National Library of Medicine.)

### Measuring Out-of-Pocket Spending and Total Spending on Medical Care

In addition to pharmacy spending, a measure of total OOP spending that includes both pharmacy and medical care can be constructed. OOP spending (patient payment amounts) associated with medical claims can be constructed using several variables from APCD medical claims files.

Variables needed:

- deductible amount
- copay amount
- coinsurance amount
- plan paid amount.

Additional medical file variables may also be needed to de-duplicate claims, to select final status claims (in some APCDs), and to link medical files to member eligibility records and pharmacy claims (see Table B.1).

### Measuring Patient Characteristics and Insurance Coverage

Information from APCD member files will be used to observe demographics and the substate area of residence for insulin users in our study population.

Variables needed:

- year and month of birth
- gender^4^
- race
- ethnicity
- geography (ZIP code or FIPS county code, depending on availability).

Age, gender, and race and ethnicity may be of interest for describing the state’s insulin user population and for conducting within-state subgroup analyses describing variation across groups in OOP spending and total costs of care. Geographic variables may similarly be used for subgroup analyses comparing insulin OOP spending and total costs of care between urban and rural areas within a state (defined by Rural-Urban Continuum codes if ZIP code is available or by metropolitan/nonmetropolitan status if county codes are available).

#### Assigning Insurance Coverage Type

Information from APCD eligibility files can be used to classify the type of insurance coverage held by insulin users and to define the period when insulin users are under observation in the APCD.

Variables needed:

- payer code
- member insurance product/category code
- start year of submission
- start month of submission
- medical coverage under this plan
- pharmacy coverage under this plan
- primary insurance indicator
- coverage type
- market category code
- HDHP indicator.

Using guidance from RAND’s prior work for ASPE (Carman and Dworsky, 2020), eligibility file data can be used to assign individuals to one of five broad coverage types:

1. Medicare
2. Medicaid
3. ESI
4. Marketplace coverage
5. other nongroup coverage.

## Suggested Approach for Reporting Findings

The following tables could be constructed to illustrate variation in insulin costs from a single state for a single year.

### Tables Describing OOP Price per 30 Days’ Insulin Supply

Table B.2 below provides the structure of an example table designed to address the first research question, describing the OOP price per insulin prescription for all prescription fills observed in the APCD. Example Table 1 would present averages for the APCD and stratified by type of coverage, while Example Table Shell 2 (which would have a structure parallel to Example Table 1, but with different stratification) presents results for subgroups of insulin users.

- Example Table 1: Average OOP prices for 30-day insulin supply, by type of coverage
  – Sample: all insulin prescription fills in APCD
  – Variables used for stratification (subsamples):
    ■ type of coverage
  – Statistics to report:
    ■ mean, standard deviation, and quantiles of OOP price per 30-day supply, averaged over all insulin prescriptions observed in APCD
    ■ proportion of fills with OOP price per 30-day supply falling into intervals.
- Example Table 2: Average OOP price for 30-day insulin supply: by demographic subgroup
  – Sample: all insulin prescription fills in APCD
  – Variables used for stratification (subsamples):
    ■ gender and age
    ■ race and ethnicity (if data sufficiently complete)
    ■ urban/rural geography
  – Statistics to report: same as Example Table 1.

### Tables Describing Annual OOP Costs and Total Cost of Care for Insulin Users

To examine OOP spending and the total cost of care for insulin users, we propose restricting the population of interest to individuals with full-year continuous coverage in the same health plan (i.e., same coverage type and same health plan) with no insurance transitions or gaps in coverage. Example Table 3 (illustrated as Table B.3 below) would report the average, standard deviation, and quantiles of OOP and total spending for insulin users, stratified by type of coverage (as above) to allow for comparisons across payers and facilitate comparisons across states with different sources of health coverage.

- Example Table 3: Annual OOP spending and total cost of care for insulin users, by type of coverage
  – Sample: insulin users with full-year (12 months) continuous coverage
  – Variables used for stratification (subsamples):
    ■ type of coverage
  – Statistics to report:
    ■ mean of costs by type:
      ■ OOP costs
        ■ insulin OOP costs
        ■ diabetes drug OOP costs
        ■ all prescription OOP costs
      ■ total OOP costs (pharmacy + medical)
        ■ total costs of care
        ■ prescription drugs
        ■ medical care
      ■ total cost of care (prescription + medical)
    ■ mean, standard deviation, and quantiles.

Table B.2 Example Table Reporting Average OOP Prices for 30-Day Insulin Supply, by Type of Coverage

| Coverage Source
Statistic | Medicare | Medicaid | ESI | Marketplace | Other Nongroup | Total
Mean OOP price (Standard deviation)
Minimum
25th percentile
50th percentile
75th percentile
90th percentile
95th percentile
Maximum
Proportion of fills with OOP cost per 30-day supply in range:
<= $35
$35.01 to $50
$50.01 to $100
> $100
N prescriptions
N unique persons

Table B.3 Example Table Reporting Average Annual OOP Spending and Total Cost of Care for Insulin Users, by Type of Coverage

| Coverage Source
Statistic | Medicare | Medicaid | ESI | Market-place | Other Nongroup | Total
OOP costs
Insulin OOP costs
Diabetes drug OOP costs
All prescription OOP costs
Total OOP costs (pharmacy + medical)
Total costs of care
Prescription drugs
Medical care
Total cost of care (prescription + medical)
N person-year observations
N unique persons

### Multi-State Comparisons

We have laid out the tables described above on the assumption that they could be produced using identical specifications in multiple state APCDs. Additional comparisons of mean OOP prices or annual spending across states might be of interest and could be conducted using quantities estimated for the tables listed above.

## Anticipated Challenges and Strategies for Addressing Them

We anticipate several challenges that will arise in this use case. In some instances, these are inherent limitations of using claims data to study insulin pricing, while in other instances, the challenges arise specifically in the context of APCDs.

### Limitations in Measuring OOP and Total Costs Using Pharmacy Claims Data

Despite the advantages of APCD data for accurately measuring patient cost-sharing on pharmacy claims, APCDs have important limitations for measuring OOP costs paid by insulin users. Key missing information about patient OOP costs includes the following:

1. Insurance premiums—a component of OOP spending that can contribute to patient financial burden and that may be affected by policies that make insurance coverage more generous—are not observed in the CDL, although they are collected by at least one participant state.
2. Coupons and OOP spending not associated with insurance claims are not observed.
3. Patient Affordability Program participation and generosity are not observed.

Because Medicare patients are known to be a population that has faced high OOP costs for insulin, we also note a major limitation of APCD data for studying insulin OOP spending for Medicare beneficiaries in particular:

4. Part D Low-Income Subsidy (LIS) status is not directly observed in APCD submissions.

The Part D LIS, which reduces patient cost-sharing and premium payments in Medicare Part D, is not typically collected in APCD data, meaning that more investigation may be needed to verify that insurers that submit Part D plan data to APCDs distinguish between patient cost-sharing and cost-sharing amounts covered by CMS through LIS. To the extent that insurers report the total of patient cost-sharing and LIS payments in the APCD field for patient cost-sharing, OOP spending on prescription drugs for LIS-eligible Medicare beneficiaries may be overstated in APCD data.

We also note that, like other pharmacy claims data, measures of total drug spending based on the APCD are likely to overstate total prescription drug spending because they do not contain information about manufacturer rebates provided to payers.

## APCD Is Not Representative of State Population (Missing Populations)

APCDs typically contain data on the entire population with certain types of public and nongroup coverage but do not capture the entire universe of individuals with health insurance in a state for several reasons, most notably the omission of several federal programs and incomplete data submission from ERISA-regulated ESI plans due to the Gobeille v. Liberty Mutual Insurance Company decision. These limitations and their implications for the use case described here are discussed more fully below.

We also acknowledge that APCD data do not include the uninsured, who are the group most exposed to high OOP spending due to high insulin list prices. Even statewide estimates from an APCD (which may require very strong assumptions) would at best reflect OOP spending for the insured population, not the uninsured.

The population of interest for any analysis using APCD data must be defined to be clear about the applicability of the estimates to insured populations with certain types of insurance. These issues, discussed below, are especially relevant for a multi-state analysis.

### Limitations Related to Federal Health Plans and Health Systems

For those with comprehensive health insurance coverage through federal insurance sources (e.g., FEHB and TRICARE), it may be reasonable to redefine the population of interest for the study to exclude individuals with these types of coverage. However, federal health systems (VHA and IHS) that are characterized by high rates of concurrent federal and nonfederal coverage pose a greater challenge for interpreting APCD-based analyses because APCDs do not typically have information about individuals’ eligibility for care from these systems.

In the context of insulin pricing, the threat to external validity may be limited if patients with concurrent federal and nonfederal coverage can be assumed to obtain insulin either exclusively through the federal system (in which case they would not appear as insulin users in the APCD) or exclusively through their APCD-covered insurance (in which case the APCD would accurately reflect their OOP spending on insulin). We think it is unlikely that this assumption would hold in practice, but auxiliary analyses using the MEPS-HC or similar household survey data could be used to evaluate the validity of this assumption.

### Limitations Related to ERISA Plans

The challenge posed by ERISA plans is different in nature because it affects the completeness of APCD data on the state’s population with ESI coverage (which is the most prevalent source of insurance coverage in the United States). ERISA plans may differ systematically from fully insured plans (which are generally mandated to submit data to APCDs), in which case it may be invalid to extrapolate from ESI plans observed in APCD data to the rest of the ESI sector.

### Potential Approaches to Addressing Limitations

Despite these limitations, it may still be of interest to report a single number summarizing the OOP price of insulin for the state’s insured population. Under the very strong assumption that the prevalence of insulin use and the OOP price is identically distributed between individuals with ERISA and non-ERISA ESI plans within a state after conditioning on age, gender, and metropolitan status, it would be possible to extrapolate OOP prices from APCD data to the ERISA-regulated segment of the ESI market in order to produce an estimate of the average OOP price in a state for ESI-covered individuals.

This extrapolation would require outside data on the joint distribution of type of coverage, age, gender, and metropolitan status within the state (e.g., using the American Community Survey or Current Population Survey Annual Socioeconomic Supplement) to derive analysis weights that could be used to reweight the APCD population to match the demographic and geographic distribution of individuals with ESI coverage within the state. Similar extrapolations could be done to produce statewide estimates for the population of individuals with APCD-covered insurance sources (Medicaid, Medicare, ESI, Marketplace, and other nongroup) based on outside estimates of the covered population.

The potential advantage of developing such weights is that they could also be used to facilitate multi-state comparisons—e.g., comparing OOP spending on insulin between states with different distributions of insurance sources, age, gender, and metropolitan residence by reweighting both states’ data to match a fixed population structure and distribution of coverage types. Such a comparison may be of interest for states interested in benchmarking or for policy evaluation in future work.

A potential challenge in developing such weights for the study of insulin OOP costs is that accurate state-level estimates of diabetes prevalence or insulin utilization rates (defined as the proportion of covered individuals who are insulin users) by type of insurance may not be readily available. More-accurate estimates may be possible in states with state-specific health interview surveys (such as the California Health interview Survey or Colorado Health Access Survey). However, the validity of the strong assumptions needed for this approach would need to be evaluated carefully.

## Demographic Variables, Including Race and Ethnicity, Are Often Incomplete

APCD data on race and ethnicity is often incomplete, especially for those with private insurance coverage. This will limit our ability to conduct within-state subgroup analyses and may reduce the comparability of subgroup estimates across states. In states where name and street address are collected, this limitation could potentially be addressed using a validated imputation algorithm, such as the RAND-developed Bayesian Improved Surname Geocoding method (RAND Corporation, undated).

## Limited Information About Income and Economic Status

High OOP spending on insulin is especially burdensome for lower-income patients. However, APCD data typically lack information about family income or other individual-level measures of economic status. In the absence of linkages to data that more directly measure economic status (such as earnings records from the state unemployment system or tax return data), APCD data are not ideal for analyses focused on insulin affordability or cost burden (sometimes defined by comparing OOP spending to various measures of monthly income).

## Limitations of APCD Specific to a Multi-State Approach

### Comparability of Data Elements and Derived Variables Is Uncertain Without Careful Investigation

In general, analysts considering a multi-state comparison of OOP and total costs for insulin users would need to carefully evaluate the comparability across states of data elements used in the analysis to ensure that the same variable measures the same construct in different states. While code sets for diagnoses, procedures, and drug codes are uniform across states, differences in data intake, quality control thresholds applied to submissions, business rules, de-duplication of claims, or other steps in the data pipeline could lead to differences across states in the relationship between values measured in the APCD and actual costs borne by patients or payers. These issues are discussed further in Chapter 3.

One possible strategy for addressing these challenges might be to reframe the research questions considered in multi-state analyses to focus on changes over time within states, rather than comparing the level of spending in cross-section at a given point in time. Such analyses could be more robust to certain forms of measurement error caused by differences in states’ data, such as differences in de-duplication that result in overcounting of costs by a proportional constant amount. Analytic techniques such as linear or generalized linear regression models that include payer fixed effects could then be used to obtain consistent estimates of changes in spending under different and arguably weaker assumptions than might be necessary to draw valid conclusions about differences in the level of OOP costs or total spending.

The value of multi-state analyses that focus on within-state changes over time will ultimately depend on the objectives of the states or research funders. Some questions of interest—e.g., "How much more or less do insulin patients pay in Colorado than in Utah?"—would not be well served by such methods. However, analytic methods that focus on within-state changes may be very well suited to questions about the effects of statewide policies, such as "Did implementation of insulin pricing reforms in Colorado reduce OOP spending by commercially insured insulin users relative to a comparison group of insulin users in Utah?" (In fact, the Agency for Healthcare Research and Quality funded a study in 2022 that will use the Colorado and Utah APCDs to address this question.^5^)

### Additional Challenges with Demographic Variables

In addition to incomplete race/ethnicity data in many state APCDs, cross-state comparisons that incorporate demographic information may be hampered by differing rates of data completeness. States also vary in the code sets or accepted values used for race and ethnicity, which may further complicate comparisons across states.

As noted above, imputation could be used to assign comparable codes for cross-state comparisons involving subgroup estimates based on race or ethnicity. However, not all states collect or release name and street address data needed to perform reliable imputations of race and ethnicity, so the feasibility of this approach would depend on which states are participating in the analysis.

### Differences in APCD Completeness and Missing Populations May Limit Comparability of Outcomes and Estimated Effects Across States

Averages calculated for the APCD population as a whole are likely not comparable across states due to differences in APCD coverage and data submission from different sources, and they cannot be assumed to be representative of the state population.

Comparisons within certain coverage sources may be more appropriate, but the value of such comparisons will depend on the completeness of APCD data, which is likely to vary across types of payers and may differ across states for specific payer types:

- Within-insurance-type comparisons for government payers (Medicare and Medicaid) may be more feasible than comparison within commercial coverage types, but inquiries with state APCD administrators about the completeness and availability of these data (especially Medicare data) would be important for guiding the interpretation of any such comparisons.
- Within-insurance-type comparisons for Marketplace and other nongroup insurance types are likely possible, but interpretation of such comparisons would need to account carefully for other potential differences in the populations with each coverage type (e.g., state decisions around Medicaid expansion).
- Within-insurance-type comparisons for ESI are likely to be the most problematic due to differences across states in the proportion of ESI enrollees who are covered by ERISA plans, in the extent of voluntary submission by ERISA plans, and in the composition of enrollees in ERISA plans that voluntarily submit.

As discussed above, analysis weights that reweight APCD data to match external coverage estimates could potentially be used to facilitate comparisons across states with differing levels of data completeness for specific types of coverage.

2 Examples of datasets commonly used in this literature include the Medical Expenditure Panel Survey—Household Component (MEPS-HC) and commercial claims databases that may have limited geographic detail and are unlikely to be representative at the state level, such as Marketscan or Optum.

3 CO ST § 10–16-151; UT ST § 31A-22–626; WA ST 48.43.780, made permanent by 2023 Wash. Legis. Serv. Ch. 16 (S.S.B. 5729); and MN ST § 62Q.48.

4 States vary in whether sex or gender is collected; the CDL uses a field for sex.

5 See NIH RePORTER (undated) for additional details on this work in progress.