# Appendix A Semistructured Discussion Guides

ASPE contracted RAND to conduct a series of discussions with stakeholders in the spring and summer of 2023 covering challenges and strategies for using APCDs for patient-centered outcomes research and multi-state research—with a focus on missing data, missing populations, and data linkages.

One-on-one discussions were held with state APCD leaders in six states, four data vendors that provide services to state APCDs, and four independent researchers from academic and nonprofit organizations who have conducted research using multiple state APCDs. In addition, two one-hour group discussions with participants from five states were held to discuss linking APCD data to additional data sources, such as vital records, hospital discharge data, and cancer registries.

Full details about the methods used for this project are described in Chapter 1. The discussion guides used in this project are included below.

## Initial State Discussion Guide

1. Is your APCD data currently being used for any multi-state research or use cases, either by your agency or outside researchers? Has there been any multi-state work in the past?
2. In thinking about analyses that may use APCD data from multiple states, what types of research questions or "use cases" might be most interesting to you and your state?
  a. Are there issues of mutual policy interest to people served by federal and state health programs that lend themselves to research using APCDs?
  b. In your opinion, what issues would be of most interest to inform patient or provider decisionmaking?
  c. [If time allows] In your opinion, how can APCD data be used to generate new evidence on the safety, effectiveness, and patient outcomes associated with interventions used in health care?
  d. [If time allows] In your opinion, how can APCDs be used to improve knowledge about new treatment and technologies used in health care?
3. Are there challenges in using your state’s APCD for a multi-state analysis today? We’re curious about data gaps—for example, are there data that are missing or not comparable to other states that may limit a multi-state analysis?
  a. [If yes] What would be needed to make cross-state comparisons more possible?
  b. [If yes] How can gaps be filled? Can existing data be standardized and major gaps filled to allow cross-state comparisons?
  c. [If time allows] Any ideas about what methods would be useful for studying patient outcomes over time, across settings, and across states given these data challenges?
4. To what extent do missing data raise concerns about APCD research findings or the value of APCDs? For example, limited data from ERISA plans and Medicare.
  a. Has your state taken steps to address missing data challenges in the APCD? If yes, which problems have you tried to address, and what steps have been implemented? What steps have been planned or discussed, but not yet implemented?
  b. What can be done to facilitate data submission by health plans covered under ERISA?
5. What are strategies to improve data around equity? This may include race/ethnicity, rural residence, gender identity, preferred language, disability status, and income.
6. To what extent can you follow individuals within your state longitudinally across payers? To what extent can you track individuals over settings of care?
  a. Do limitations in your ability to observe individuals longitudinally across payers restrict the value of the APCD for answering certain research questions?
  b. [If limitations acknowledged] What has been done or could be done in your state to address this limitation?
7. [If time allows] Are there specific policies (in your state or at the federal level) that present barriers to improving data quality and completeness?
8. Do you think a common data application could facilitate research using APCD from multiple states? By a common data application, we mean a single data request form that could be submitted by external researchers to request data from multiple states simultaneously.
  a. [If yes] In what ways?
  b. [If no] Why not?
  c. What features would make a common data application more valuable for your state?
9. What else could be done to facilitate research using APCD data from multiple states?

## Additional Items Included in Researcher Discussion Guide

Discussions with researchers utilized all the questions from the Initial State Discussion Guide, rephrased to be relevant to researchers, plus the following questions:

1. What challenges have you encountered in conducting multi-state analyses using APCDs?
  a. Potential probes:
    i. Obtaining data?
    ii. Cleaning data?
    iii. Analyzing data?
    iv. Missing populations? Examples include lack of data from Federal Employees Health Benefits (FEHB) Program and ERISA plans.
    v. Missing data? Examples include race/ethnicity, preferred language, gender identity.
    vi. Following individuals over time and across settings?
    vii. [if time allows/topic arises] Varying data quality across states?
  b. Probe: Were challenges consistent or different across states?
2. In thinking about analyses that may use APCD data from multiple states, what types of research questions or “use cases” might be most interesting to you?
  a. In your opinion, what issues would be of most interest to inform patient or provider decisionmaking?
  b. In your opinion, how can APCD data be used to generate new evidence on the safety, effectiveness, and patient outcomes associated with interventions used in health care?
  c. In your opinion, how can APCDs be used to improve knowledge about new treatment and technologies used in health care?

## Additional Items Included in Vendor Discussion Guide

Discussions with data vendors utilized all the questions from the Initial State Discussion Guide, rephrased to be relevant to data vendors, plus the following questions:

1. Which state APCDs are you working with and in what capacity?
  a. [Probe as needed] What kind of services do you provide?
  b. [Probe as needed] Approximately how many/which states do you work with?

## Data Linkages Discussion Guide

1. What types of data do you currently link to APCD data?
2. Can you tell me a little bit about the data linkage process?
3. Why did you move forward with this linkage/these linkages?
4. What were the key challenges in linking these data?
5. What are the key challenges in using these linked data?
6. What do you see as the "value-added" for linking these data? In other words, what can you do with the linked data that you cannot do with APCD data alone?
7. How have these linked data been used either by your agency, other agencies in your state, or by outside researchers? Have the linked data been used in any multi-state research studies?
8. In thinking about analyses that may use linked APCD data from multiple states, what types of research questions or "use cases" might be most interesting to you and your state?
9. How might data linkage be used to address health inequities in your state? This may include inequities around race/ethnicity, rural residence, gender identity, preferred language, disability status, and income.
10. Are there any resources or activities that you think could help states harmonize their efforts to link APCD data with other sources?
11. What future efforts to link APCDs to other data sources are planned by your state?