# References

1 Ahmedani, B.K., Simon, G.E., Stewart, C., Beck, A., Waitzfelder, B.E., Rossom, R., … Solberg, L.I. (2014). Health care contacts in the year before suicide death. Journal of General Internal Medicine, 29(6), 870–877. 10.1007/s11606-014-2767-3.
2 Suicide Prevention Resource Center. (2019). Financing suicide prevention in health care systems: Best practices and recommendations. Waltham, MA: Education Development Center, Inc. Retrieved from https://zerosuicide.edc.org/resources/resource-database/financing-suicide-prevention-health-care-systems-best-practices-and.
3 Ahmedani, B.K., Stewart, C., Simon, G.E., Lynch, F., Lu, C.Y., Waitzfelder, B.E., … Williams, L.K. (2015). Racial/ethnic differences in healthcare visits made prior to suicide attempt across the United States. Medical Care, 53(5), 430–435. 10.1097/MLR.0000000000000335.25872151
4 Ahmedani, B.K., Westphal, J., Autio, K., Elsiss, F., Peterson, E.L., Beck, A., … Simon, G.E. (2019). Variation in patterns of health care before suicide: A population case-control study. Preventive Medicine, 127, 105796. 10.1016/j.ypmed.2019.105796.31400374
5 Ribeiro, J.D., Gutierrez, P.M., Joiner, T.E., Kessler, R.C., Petukhova, M.V., Sampson, N.A., … Nock, M.K. (2017). Healthcare contact and suicide risk documentation prior to suicide death: Results from the Army Study to Assess Risk and Resilience in Servicemembers (Army STARRS). Journal of Consulting & Clinical Psychology, 85(4), 403–408. 10.1037/ccp0000178.28333538
6 Jack, S.P.D. (2018). Surveillance for violent deaths--National Violent Death Reporting System, 27 States, 2015. MMWR. Surveillance Summaries, 67. 10.15585/mmwr.ss6711a1.
7 World Health Organization. (2014). Preventing suicide: A global imperative: World Health Organization.
8 Knox, K.L., Litts, D.A., Talcott, G.W., Feig, J.C., & Caine, E.D. (2003). Risk of suicide and related adverse outcomes after exposure to a suicide prevention programme in the US Air Force: Cohort study. BMJ, 327(7428), 1376. 10.1136/bmj.327.7428.1376.14670880
9 Institute of Medicine. (2001). Crossing the quality chasm: A new health system for the 21st century. Washington, DC: The National Academies Press: Institute of Medicine.
10 Coffey, C.E. (2007). Building a system of perfect depression care in behavioral health. Joint Commission Journal on Quality & Patient Safety, 33(4), 193–199. 10.1016/s1553-7250(07)33022-5.17441556
11 Coffey, M.J., Coffey, C.E., & Ahmedani, B.K. (2015). Suicide in a health maintenance organization population. JAMA Psychiatry, 72(3), 294–296. 10.1001/jamapsychiatry.2014.2440.25607598
12 Office of the Surgeon General & National Action Alliance for Suicide Prevention. (2012). 2012 National strategy for suicide prevention: Goals and objectives for Action: A report of the U.S. Surgeon General and of the National Action Alliance for Suicide Prevention. Washington, DC: U.S. Department of Health and Human Services.
13 Hogan, M.F., & Grumet, J.G. (2016). Suicide prevention: An emerging priority for health care. Health Affairs, 35(6), 1084–1090. 10.1377/hlthaff.2015.1672.27269026
14 National Action Alliance for Suicide Prevention, Clinical Care & Intervention Task Force. (2012). Suicide Care in Systems Framework. Retrieved from https://theactionalliance.org/resource/suicide-care-systems-framework.
15 U.S. Surgeon General & National Action Alliance for Suicide Prevention. The Surgeon General’s call to action: To implement the National Strategy for Suicide Prevention: Washington, DC: U.S. Department of Health and Human Services. https://www.hhs.gov/sites/default/files/sprc-call-to-action.pdf.
16 Ahmedani, B.K. (2019). Challenges and solutions in Zero Suicide implementation. Paper presented at the IASR/AFSP International Summit on Suicide Research.
17 Stanley, B., Labouliere, C.D., Brown, G.K., Green, K.L., Galfalvy, H.C., Finnerty, M.T., … Dixon, L.B. (2021). Zero suicide implementation-effectiveness trial study protocol in outpatient behavioral health using the AIM suicide prevention model. Contemporary Clinical Trials, 100, 106224. 10.1016/j.cct.2020.106224.33220488
18 Stapelberg, N.J.C., Sveticic, J., Hughes, I., Almeida-Crasto, A., Gaee-Atefi, T., Gill, N., … Turner, K. (2020). Efficacy of the Zero Suicide framework in reducing recurrent suicide attempts: Cross-sectional and time-to-recurrent-event analysis. British Journal of Psychiatry. 10.1192/bjp.2020.190.
19 Layman, D.M., Kammer, J., Leckman-Westin, E., Hogan, M., Grumet, J.G., Labouliere, C.D., … Finnerty, M. (2021). The relationship between suicidal behaviors and Zero Suicide organizational best practices in outpatient mental health clinics. Psychiatric Services. 10.1176/appi.ps.202000525.
20 Coffey, C.E. (2006). Pursuing perfect depression care. Psychiatric Services, 57(10), 1524–1526. 10.1176/ps.2006.57.10.1524.17035593
21 Mokkenstorm, J.K., Kerkhof, A.J.F.M., Smit, J.H., & Beekman, A.T.F. (2018). Is it rational to pursue zero suicides among patients in health care? Suicide & Life-Threatening Behavior, 48(6), 745–754. 10.1111/sltb.12396.29073324
22 Zero Suicide. (n.d.). Toolkit. Educational Development Center. Retrieved from https://zerosuicide.edc.org/toolkit.
23 Henry Ford Health System (HFHS). (2018). Henry Ford Zero Suicide Prevention Guidelines. Retrieved from https://www.henryford.com/services/behavioral-health/zero-suicide.
24 Brodsky, B.S., Spruch-Feiner, A., & Stanley, B. (2018). The Zero Suicide model: Applying evidence-based suicide prevention practices to clinical care. Frontiers in Psychiatry, 9. 10.3389/fpsyt.2018.00033.
25 Labouliere, C.D., Vasan, P., Kramer, A., Brown, G., Green, K., Rahman, M., … Stanley, B. (2018). “Zero Suicide”--A model for reducing suicide in United States behavioral healthcare. Suicidologi, 23(1), 22–30.29970972
26 Ahmedani, B. (2018). An evaluation of the National Zero Suicide Model across learning healthcare systems. National Institutes of Health [Project number 5UO1MH114087-02]. https://reporter.nih.gov/project-details/9538844.
27 Stanley, B., & Brown, G.K. (2008). Safety plan treatment manual to reduce suicide risk: Veteran version. University of Oklahoma Health Sciences Center. Retrieved from https://www.sprc.org/resources-programs/safety-plan-treatment-manual-reduce-suicide-risk-veteran-version.
28 Betz, M.E., Sullivan, A.F., Manton, A.P., Espinola, J.A., Miller, I., Camargo, C.A., … Investigators, E.-S. (2013). Knowledge, attitudes, and practices of emergency department providers in the care of suicidal patients. Depression & Anxiety, 30(10), 1005–1012. 10.1002/da.22071.23426881
29 Betz, M.E., Wintersteen, M., Boudreaux, E.D., Brown, G., Capoccia, L., Currier, G., … Harkavy-Friedman, J. (2016). Reducing suicide risk: Challenges and opportunities in the emergency department. Annals of Emergency Medicine, 68(6), 758–765. 10.1016/j.annemergmed.2016.05.030.27451339
30 Miller, M., Azrael, D., & Hemenway, D. (2006). Belief in the inevitability of suicide: Results from a national survey. Suicide and Life-Threatening Behavior, 36(1), 1–11. 10.1521/suli.2006.36.1.1.16676620
31 Larkin, C. (2019, 2019). Assessing clinician attitudes and needs in Zero Suicide implementation: The System of Safety Study. Paper presented at the IASR/AFSP International Summit on Suicide Research.
32 Turner, K., Sveticic, J., Almeida-Crasto, A., Gaee-Atefi, T., Green, V., Grice, D., … Stapelberg, N.J. (2020). Implementing a systems approach to suicide prevention in a mental health service using the Zero Suicide Framework. Australian & New Zealand Journal of Psychiatry, 1–13. 10.1177/0004867420971698.
33 Grumet, J.G., Hogan, M.F., Covington, D.W., & Johnson, K.E. (2019). Compliance standards pave the way for reducing suicide in health care systems. Journal of Health Care Compliance, 21(1), 17–26.
34 Wakai, S., Schilling, E.A., Aseltine, R.H. Jr., Blair, E.W., Bourbeau, J., Duarte, A., … Welsh, A. (2020). Suicide prevention skills, confidence and training: Results from the Zero Suicide Workforce Survey of behavioral health care professionals. SAGE Open Medicine, 8, 1–12. 10.1177/2050312120933152.
35 Vermont Department of Mental Health. (2019). Implementing Zero Suicide.
36 Holoshitz, Y., Brodsky, B., Zisook, S., Bernanke, J., & Stanley, B. (2019). Application of the Zero Suicide model in residency training. Academic Psychiatry: Journal of the American Association of Directors of Psychiatric Residency Training & Association for Academic Psychiatry, 43(3), 332–336. 10.1007/s40596-019-01022-0.
37 Yarborough, B.J.H., Ahmedani, B.K., Boggs, J.M., Beck, A., Coleman, K.J., Sterling, S., … Simon, G.E. (2019). Challenges of population-based measurement of suicide prevention activities across multiple health systems. EGEMS, 7(1), 13. 10.5334/egems.277.30993146
38 Horowitz, L.M., Bridge, J.A., Teach, S.J., Ballard, E., Klima, J., Rosenstein, D. L., … Pao, M. (2012). Ask Suicide-Screening Questions (ASQ): A brief instrument for the pediatric emergency department. Archives of Pediatrics & Adolescent Medicine, 166(12), 1170–1176. 10.1001/archpediatrics.2012.1276.23027429
39 Warren, M.B., & Smithkors, L.A. (2020). Suicide prevention in the U.S. Department of Veterans Affairs: Using the evidence without losing the narrative. Psychiatric Services. 10.1176/appi.ps.201900482.
40 Picard, E.H., & Rosenfeld, B. (2021). How clinicians incorporate suicide risk factors into suicide risk assessment. Crisis: Journal of Crisis Intervention & Suicide Prevention, 42(2), 100–106. 10.1027/0227-5910/a000694.
41 Simon, G.E., Johnson, E., Lawrence, J.M., Rossom, R.C., Ahmedani, B., Lynch, F.L., … Shortreed, S.M. (2018). Predicting suicide attempts and suicide deaths following outpatient visits using electronic health records. American Journal of Psychiatry, 175(10), 951–960. 10.1176/appi.ajp.2018.17101167.29792051
42 McCarthy, J.F., Bossarte, R.M., Katz, I.R., Thompson, C., Kemp, J., Hannemann, C.M., … Schoenbaum, M. (2015). Predictive modeling and concentration of the risk of suicide: Implications for preventive interventions in the U.S. Department of Veterans Affairs. American Journal of Public Health, 105(9), 1935–1942. 10.2105/AJPH.2015.302737.26066914
43 Belsher, B.E., Smolenski, D.J., Pruitt, L.D., Bush, N.E., Beech, E.H., Workman, D.E., … Skopp, N.A. (2019). Prediction models for suicide attempts and deaths: A systematic review and simulation. JAMA Psychiatry, 76(6), 642–651. 10.1001/jamapsychiatry.2019.0174.30865249
44 Simon, G.E., Yarborough, B.J., Rossom, R.C., Lawrence, J.M., Lynch, F.L., Waitzfelder, B.E., … Shortreed, S.M. (2019). Self-reported suicidal ideation as a predictor of suicidal behavior among outpatients with diagnoses of psychotic disorders. Psychiatric Services, 70(3), 176–183. 10.1176/appi.ps.201800381.30526341
45 Brown, G.K., Have, T.T., Henriques, G.R., Xie, S.X., Hollander, J.E., & Beck, A.T. (2005). Cognitive therapy for the prevention of suicide attempts: A randomized controlled trial. JAMA, 294(5), 563–570. 10.1001/jama.294.5.563.16077050
46 Stanley, B., Brown, G., Brent, D.A., Wells, K., Poling, K., Curry, J., … Hughes, J. (2009). Cognitive-Behavioral Therapy for Suicide Prevention (CBT-SP): Treatment model, feasibility, and acceptability. Journal of the American Academy of Child & Adolescent Psychiatry, 48(10), 1005–1013. 10.1097/CHI.0b013e3181b5dbfe.19730273
47 Fernandez, E., Salem, D., Swift, J.K., & Ramtahal, N. (2015). Meta-analysis of dropout from cognitive behavioral therapy: Magnitude, timing, and moderators. Journal of consulting & clinical psychology, 83(6), 1108–1122. 10.1037/ccp0000044.26302248
48 Zero Suicide. Centerstone caring letter--English and Spanish. Education Development Center, Inc. Retrieved from https://zerosuicide.edc.org/resources/resource-database/centerstone-caring-letter-english-and-spanish.
49 Betancourt, J.A., Rosenberg, M.A., Zevallos, A., Brown, J.R., & Mileski, M. (2020). The impact of COVID-19 on telemedicine utilization across multiple service lines in the United States. Healthcare, 8(4), 380. 10.3390/healthcare8040380.33019667
50 Anthony, B. Jr. (2020). Implications of telehealth and digital care solutions during COVID-19 pandemic: A qualitative literature review. Informatics for Health & Social Care, 46(1), 68–83. 10.1080/17538157.2020.1839467.33251894
51 Dimeff, L.A., Jobes, D.A., Chalker, S.A., Piehl, B.M., Duvivier, L.L., Lok, B.C., … Koerner, K. (2020). A novel engagement of suicidality in the emergency department: Virtual collaborative assessment and management of suicidality. General Hospital Psychiatry, 63, 119–126. 10.1016/j.genhosppsych.2018.05.005.29934033
52 Dexter-Mazza, E.T., & Freeman, K.A. (2003). Graduate training and the treatment of suicidal clients: The students’ perspective. Suicide & Life-Threatening Behavior, 33(2), 211–218. 10.1521/suli.33.2.211.22769.12882422
53 Substance Abuse and Mental Health Services Administration (SAMHSA). (2020). Treatment for Suicidal Ideation, Self-Harm, and Suicide Attempts Among Youth. Rockville, MD: National Mental Health and Substance Use Policy Laboratory [SAMHSA Publication No. PEP20-06-01-002].
54 D’Anci, K.E., Uhi, S.; Giradi, G.; & Martin, C. (2019). Treatments for the prevention and management of suicide: A systematic review. Annals of Internal Medicine, 171(5), 334–342. 10.7326/M19-0869.31450239
55 Roszko, P.J.D., Ameli, J., Carter, P.M., Cunningham, R.M., & Ranney, M.L. (2016). Clinician attitudes, screening practices, and interventions to reduce firearm-related injury. Epidemiologic Reviews, 38(1), 87–110. 10.1093/epirev/mxv005.26905894
56 Boggs, J. (2019). Safety planning: What does it mean to you? Paper presented at the AFSP International Summit on Suicide Research.
57 Massey, A.E., Borghesani, P., Stuber, J., Ratzliff, A., Rivara, F.P., & Rowhani-Rahbar, A. (2020). Lethal means assessment in psychiatric emergency services: Frequency and characteristics of assessment. Archives of Suicide Research, 1–15. 10.1080/13811118.2020.1783411.
58 Luxton, D.D., June, J.D., & Comtois, K.A. (2013). Can postdischarge follow-up contacts prevent suicide and suicidal behavior? Crisis, 34(1), 32–41. 10.1027/0227-5910/a000158.22846445
59 Comtois, K.A., Kerbrat, A.H., DeCou, C.R., Atkins, D.C., Majeres, J.J., Baker, J.C., & Ries, R.K. (2019). Effect of augmenting standard care for military personnel with brief caring text messages for suicide prevention: A randomized clinical trial. JAMA Psychiatry, 76(5), 474–483. 10.1001/jamapsychiatry.2018.4530.30758491
60 Miller, I.W., Carmargo, C.A. Jr., Arias, S.A., Sullivan, A.F., Allen, M.H., Goldstein, A.B., … ED-SAFE Investigators. (2017). Suicide prevention in an emergency department population: The ED-SAFE Study. JAMA Psychiatry, 74(6), 563–570. 10.1001/jamapsychiatry.2017.0678.28456130
61 Suicide Prevention Resource Center. (2017). Zero Suicide organizational self-study.
62 Mental Health Colorado. (2019). ZERO SUICIDE.
63 Utah Department of Substance Abuse and Mental Health. (2020). Zero Suicide Framework.
64 Tennessee Suicide Prevention Network (TSPN). (2020). Zero Suicide Initiative.
65 Suicide Prevention Resource Center. (2019). Missouri Department of Mental Health Outcome Story.
66 National Institute of Mental Health (NIMH). (2016). NIMH Funds 3 ‘Zero Suicide’ Grants.
67 Indian Health Service (IHS). (2017). Zero Suicide Initiative Sites | IHS Zero Suicide Initiative. Zero Suicide.
68 Substance Abuse and Mental Health Services Administration (SAMHSA). (2017). SM-17-006 Individual Grant Awards in 2017.
69 Substance Abuse and Mental Health Services Administration (SAMHSA). (2018). SM-17-006 Individual Grant Awards in 2018.
70 Substance Abuse and Mental Health Services Administration (SAMHSA). (2020). SM-20-015 Individual Grant Awards in 2020. Retrieved from https://www.samhsa.gov/grants/awards/2020/SM-20-015.
71 National Academies of Sciences, Engineering, & Medicine. (2019). Improving care to prevent suicide among people with serious mental illness: Proceedings of a workshop. Washington, DC: National Academies Press.
72 Suicide Prevention Resource Center. (2019). Safer suicide care billing tip sheet. Retrieved from https://zerosuicide.edc.org/resources/resource-database/safer-suicide-care-billing-tip-sheet.
73 Suicide Prevention Resource Center. (2019). Suicide care pathway coding for primary care.
74 Suicide Prevention Resource Center. (2019). Wellstone Regional Hospital outcome story.
75 Suicide Prevention Resource Center. (2019). Riveredge Hospital outcome story.
76 Suicide Prevention Resource Center. (2019). Chickasaw Nation Departments of Health and Family Services outcome story.
77 Dunlap, L.J., Orme, S., Zarkin, G.A., Arias, S.A., Miller, I.W., Carmargo, C.A. Jr., … Boudreaux, E.D. (2019). Screening and intervention for suicide prevention: A cost-effectiveness analysis of the ED-SAFE Interventions. Psychiatric Services, 70(12), 1082–1087. 10.1176/appi.ps.201800445.31451063
78 Denchev, P., Pearson, J.L., Allen, M.H., Claassen, C.A., Currier, G.W., Zatzick, D.F., & Schoenbaum, M. (2018). Modeling the cost-effectiveness of interventions to reduce suicide risk among hospital emergency department patients. Psychiatric Services, 69(1), 23–31. 10.1176/appi.ps.201600351.28945181
79 Pil, L., Pauwels, K., Muijzers, E., Portzky, G., & Annemans, L. (2013). Cost-effectiveness of a helpline for suicide prevention. Journal of Telemedicine & Telecare, 19(5), 273–281. 10.1177/1357633X13495487.24163237
80 Park, A.-L., Gysin-Maillart, A., Müller, T.J., Exadaktylos, A., & Michel, K. (2018). Cost-effectiveness of a brief structured intervention program aimed at preventing repeat suicide attempts among those who previously attempted suicide: A secondary analysis of the ASSIP Randomized Clinical Trial. JAMA Network Open, 1(6), e183680. 10.1001/jamanetworkopen.2018.3680.30646253
81 Bernecker, S.L., Zuromski, K.L., Curry, J.C., Kim, J.J., Gutierrez, P.M., Joiner, T.E., … Bryan, C.J. (2020). Economic evaluation of brief cognitive behavioral therapy vs treatment as usual for suicidal U.S. Army soldiers. JAMA Psychiatry, 77(3), 256–264. 10.1001/jamapsychiatry.2019.3639.31774485
82 Nuckols, T.K., Keeler, E., Morton, S., Anderson, L., Doyle, B.J., Pevnick, J., … Shekelle, P. (2017). Economic evaluation of quality improvement interventions designed to prevent hospital readmission: A systematic review and meta-analysis. JAMA Internal Medicine, 177(7), 975–985. 10.1001/jamainternmed.2017.1136.28558095
83 Zero Suicide Institute. (2021). Zero Suicide Academy. Education Development Center, Inc. Retrieved from http://zerosuicideinstitute.com/zero-suicide/academy.
84 Posner, K., Brown, G.K., Stanley, B., Brent, D.A., Yershova, K.V., Oquendo, M.A., … Mann, J.J. (2011). The Columbia-Suicide Severity Rating Scale: Initial validity and internal consistency findings from three multisite studies with adolescents and adults. American Journal of Psychiatry, 168(12), 1266–1277. 10.1176/appi.ajp.2011.10111704.22193671
85 Suicide Prevention Resource Center. (2019). Assessing and managing suicide risk: Core competencies for mental health professionals. University of Oklahoma Health Sciences Center. Retrieved from https://sprc.org/resources-programs/assessing-and-managing-suicide-risk-core-competencies-mental-health-professionals.
86 The Joint Commission. (2019). Suicide prevention. Retrieved from https://www.jointcommission.org/resources/patient-safety-topics/suicide-prevention/.
87 Centers for Disease Control and Prevention. (2020). Violence prevention: NVDRS state profiles. Retrieved from https://www.cdc.gov/violenceprevention/datasources/nvdrs/stateprofiles.html.
88 Zwald, M.L., Holland, K.M., Annor, F.B., Kite-Powell, A., Sumner, S.A., Browen, D.A., … Crosby, A.E. (2020). Syndromic surveillance of suicidal ideation and self-directed violence--United States, January 2017-December 2018. MMWR, 69(4), 103–108.31999688
89 Calculating the Costs of Child Welfare Services Workgroup. (2013). Cost analysis in program evaluation: A guide for child welfare researchers and service providers. Washington, DC: Children’s Bureau, Administration for Children and Families, U.S. Department of Health and Human Services.
90 Madsen, T.E., Bennett, A., Groke, S., Zink, A., McCowan, C., Hernandez, A., … Quick, N. (2009). Emergency department patients with psychiatric complaints return at higher rates than controls. Western Journal of Emergency Medicine, 10(4), 268–272.20046248