# Acknowledgments

We gratefully acknowledge contributions of the following subject-matter experts who were consulted on this project: Brian Ahmedani (Henry Ford Health), Julie Goldstein Grumet (Education Development Center), Barbara Stanley (Columbia University, and Virna Little (City University of New York). We are also grateful for the participation of the following organizations and communities who participated in the case studies for this project: Henry Ford Health System (HFHS), Centerstone, AtlantiCare, Mental Health Center of Greater Manchester (MHCGM), Kaiser Permanente, Chickasaw Nation, Riveredge Hospital, Universal Health Services (UHS), and Avera Health.

Although the findings presented in this report are solely the responsibility of RTI International, we recognize the valuable involvement and direction of our project leaders: Joel Dubenitz (ASPE) and Savannah Kidd (SAMHSA).