# Executive Summary

Among people in the United States who die by suicide, about half received health care services in the 30 days prior to their death.^1^ Health systems can play a central role in suicide prevention by identifying those at elevated risk of suicide and by providing the treatments and other interventions that are supported by the best available evidence. Zero Suicide is a system-wide change to improve the quality and safety of care for those at risk of suicide; it strives to prevent all suicide deaths among patients. A toolkit (https://zerosuicide.sprc.org/toolkit) and numerous resources have been developed to guide health systems in the implementation of Zero Suicide. The purpose of this study was to identify additional examples of Zero Suicide implementation and describe approaches to sustaining Zero Suicide financially and operationally. Challenges to implementation and sustainability were identified, as were approaches to overcoming those challenges.

## Review of the Literature

The published literature has highlighted select challenges to implementing Zero Suicide. For example, providers may be initially skeptical of the idea of Zero Suicide, and ongoing training is needed to support providers. Additionally, different identification strategies are used across health systems, resulting in different thresholds of suicide risk. Regular oversight of the identification, engagement, and treatment approaches is needed to maintain fidelity to protocols.

The details in the published and grey literature about sustaining Zero Suicide are much less extensive than those regarding implementation. Several organizations have received federal grants to support their implementation of Zero Suicide. A report was also published on approaches to financing suicide prevention among health care systems.^2^ Although several studies have explored the potential cost-effectiveness of elements of Zero Suicide, no rigorous evaluations of the overall cost-effectiveness of Zero Suicide have been conducted.

## Case Studies

To gather additional information on the implementation and sustainability of Zero Suicide, we conducted case studies with eight health systems from across the country. These recruited case study sites include integrated health systems and organizations specializing in only behavioral health. We spoke with up to nine individuals who had been involved in Zero Suicide at each organization, ranging from Chief Executive Officers (CEOs) to physical and behavioral health providers.

## Early Adoption

Although the specific approaches to early adoption varied across organizations, all organizations described initial commitments from key senior leadership as a prerequisite for next stages of adoption and implementation of Zero Suicide. Each organization obtained preliminary information about Zero Suicide through a combination of workshops, trainings, and workforce surveys to determine implementation steps. Additionally, all organizations created or identified suicide prevention steering committees to facilitate implementation.

## Ongoing Implementation

Ongoing implementation of Zero Suicide involved establishing and embedding Zero Suicide activities into everyday practice and changing staff culture around willingness to address suicide risk in their day-to-day work. Some providers struggled to accept the responsibilities of identifying and addressing suicide risk, especially in the case of primary care providers who did not have the requisite training in mental health and suicide prevention. In response, organizations provided ongoing training and expanded integrated services with behavioral health care. Organizations also used standardized guidelines and protocols to help codify necessary shifts to workflow for enhancing suicide prevention within their organizations.

## Growth

To facilitate growth in their implementation of Zero Suicide, organizations leveraged community partnerships to carry out specific aspects of implementation, expand reach of suicide prevention practices to wider service areas, and provide further education and outreach to the community. Additionally, sites incorporated internal checks to ensure that Zero Suicide protocols were maintained, or improved, so that the needs of the patient population were met. Information sharing across electronic health records (EHRs) posed challenges for some organizations; however, dashboards and centralized documents for tracking key process and outcome measures helped identify areas for growth and improvement.

## Sustainability

Organizations shared that the decision to implement and sustain Zero Suicide was founded in a desire to save lives and improve the quality of care, not to save money. Many of the case study organizations allotted substantial internal funding to implement Zero Suicide and train staff; however, they also described the ongoing maintenance costs of Zero Suicide as minimal. Some elements of Zero Suicide (e.g., screening, safety planning, follow-up calls) were described as low-cost but having a high-impact. Over time, all but one of the organizations in the case studies diversified their funding of Zero Suicide through a variety of external funding opportunities. The organizations also observed that their investments in Zero Suicide helped offset other costs of care for patients.

Some providers and leaders expressed that a greater concern than financial sustainability was sustaining fidelity to their implemented Zero Suicide protocols and practices. Organizations mentioned that monitoring and sharing success stories was crucial to sustaining the work. Strategic community partners were also an important part of sustaining the work of Zero Suicide and making it part of the community’s identity and not just the organization’s identity.

## Policy and Practice Implications

The findings from this study have implications for health systems, state and community leaders, and national funders and decision makers. Health systems that are planning to implement Zero Suicide can expect large upfront costs to implement training and facilitate a shift in the culture around suicide prevention, but smaller ongoing costs once activities are integrated into daily practices and protocols. These changes, however, can result in cost offsets and improvement in the overall quality of patient care. Health systems can also leverage or develop community partnerships to alleviate some costs and become recognized leaders for preventing suicide.

State and community leaders can assist in the sustainability of Zero Suicide by developing networks and coalitions that offer training, mentorship, and when possible, funding to support Zero Suicide initiatives in health systems. State Medicaid agencies can also develop reimbursement opportunities for elements of Zero Suicide that are evidence-based and cost-effective. State laws can also be developed to support suicide prevention, such as suicide prevention training requirements and follow-up requirements among those at increased risk of suicide.

The continued support from national funders such as the Substance Abuse and Mental Health Services Administration (SAMHSA), Indian Health Service (IHS), and Health Resources and Services Administration (HRSA) is particularly helpful to support start-up costs related to training, establish monitoring programs and evaluations, and expand Zero Suicide within or across multiple organizations and health care settings. Health insurance companies are often the main beneficiaries of the cost offsets resulting from Zero Suicide implementation. They can play a role in reimbursing suicide prevention activities (e.g., suicide screening, brief intervention, and referral to treatment [SBIRT]) and using the mechanisms of accountable care organizations (ACOs) and hospital value-based purchasing (HVBP) to allow for shared savings among health systems that transform their approach to addressing suicide. Nationally, wider support of suicide prevention training integrated with clinical training programs can also help alleviate cost on health systems and improve the nation’s ability to prevent suicide.

## Conclusions

Study findings suggest that there are many different paths to implementing, and sustaining, Zero Suicide within health care organizations. However, a common commitment to prioritizing the identification and support of those at risk of suicide leads to improved quality of care, cost offsets, and anecdotal evidence of lives saved. The continued support of state and community leaders and national funders and decision makers can make Zero Suicide more easily sustainable across the United States.