# Acronyms

The following acronyms are mentioned in this report and/or appendices.

ACO: Accountable Care Organization
AIM-SP: Assess, Intervene, and Monitor for Suicide Prevention
AMSR: Assessing and Managing Suicide Risk
ASPE: Office of the Assistant Secretary for Planning and Evaluation
ASSIP: Attempted Suicide Short Intervention Program
B-CBT: Brief Cognitive Behavioral Therapy for Suicide Prevention
C-CFP: Centerstone Crisis Follow-up Program
C-SSRS: Columbia Suicide Severity Rating Scale
CC-HRFP: Centerstone Crisis High Risk Follow-up Program
CBT: Cognitive Behavioral Therapy
CBT-SP: Cognitive Behavioral Therapy for Suicide Prevention
CCO: Chief Clinical Officer
CEO: Chief Executive Officer
CMI: Kaiser Permanente Care Management Institute
COVID-19: Novel Coronavirus
CRP: Crisis Response Plan
DBT: Dialectical Behavior Therapy
EHR: Electronic Health Record
HFHS: Henry Ford Health System
HRSA: Health Resources and Services Administration
HVBP: Hospital Value-Based Purchasing
IHS: Indian Health Services
KPNW: Kaiser Permanente Northwest
MHALO: Mental Health and Addiction Leaders of Operations
MHCGM: Mental Health Center of Greater Manchester
NAMI: National Alliance on Mental Illness
NIMH: National Institute of Mental Health
ODMHSAS: Oklahoma Department of Mental Health and Substance Abuse Services
PHQ: Patient Health Questionnaire
QPR: Question, Persuade, Refer training
QPRT: Question, Persuade, Refer, Treat training
RQ: Research Question
SAMHSA: Substance Abuse and Mental Health Services Administration
SBIRT: Screening, Brief Intervention, and Referral to Treatment
SPC: Suicide Prevention Coordinator
TMBI: Teachable Moment Brief Intervention
TSPN: Tennessee Suicide Prevention Network
UHS: Universal Health Services
VP: Vice President