# 4 Implications and Conclusions

The organizations reflected in the case studies discussed in this report all faced challenges in their implementation and sustainability of Zero Suicide; however, they forged solutions to their challenges as they continually strived to prevent all suicide deaths among those receiving care within their health systems. The purpose of this document is to highlight approaches, challenges, and solutions to implementing and sustaining Zero Suicide, so that other health systems may be better informed in their own approach to suicide prevention. These findings have implications not only for health systems, but also for other groups of decision makers that play a role in supporting Zero Suicide across many organizations and communities. These implications are outlined below by key stakeholder groups.

## 4.1 Health Systems

Organizations that have successfully implemented and sustained Zero Suicide are founded in a focus on quality of care and preventing suicide deaths, rather than costs. This foundation often stems from the commitment of a few senior leaders who are passionate about preventing suicide deaths; however, it is spread and maintained throughout the organization by teaching about the importance of the initiative, enabling staff and providers with the skills to address suicide risk, and sharing the successes and progress that is made toward preventing suicide.

Because most providers are not extensively trained in suicide prevention in their formal education, health systems committed to Zero Suicide must invest in training their staff to perform evidence-based suicide prevention practices. This training can be a substantial cost at the beginning, but the experiences from the case studies and the evidence in the literature suggests that implementing these trainings can offset costs and improve overall quality of care.

Most of the ongoing costs of Zero Suicide can be paid for under the normal course of business. Clinical assessments and psychotherapy for those at increased risk of suicide are reimbursable through common billing codes. Ongoing training, monitoring, and oversight can be integrated into pre-existing protocols and meetings. Additional costs for things like screening, safety planning, and follow-up contacts are not typically reimbursed; however, the organizations in the case study examples in this report invested time to do the activities because they were low-cost and high-impact.

The cases in this report all predominantly funded their Zero Suicide efforts through internal funds. These initial investments in Zero Suicide qualified the organizations for local and national funding opportunities. As a result, most organizations included in this report have received additional grants to help sustain and even expand their suicide prevention services. Many of the health systems have also received positive attention from their state and local communities because of their concentrated efforts to prevent suicide.

Leveraging new or existing community partnerships was a key aspect of implementing and sustaining Zero Suicide. Some health systems partnered with local call centers to help with follow-up calls and weekend crisis calls. Others established partnerships with police and first responders to address crises in the community, with other settings of care (e.g., the emergency department) to do suicide assessment and follow-up for them, or with local nonprofits (e.g., NAMI) to help with peer-support or general trainings related to suicide prevention and awareness. As the organizations gained experience with Zero Suicide and established community partners, they also mentored other health systems in implementing Zero Suicide, thus establishing a network of Zero Suicide providers throughout the community.

## 4.2 State and Community Leaders

States can facilitate the development of community networks focused on Zero Suicide. Some states (e.g., Colorado, Tennessee, Missouri, Utah) have implemented Suicide Prevention Networks. These networks and other state organizations can offer training and support to health systems in how to implement and sustain Zero Suicide. Some states have received federal grants to support the coordination of these activities. Others have provided their own grants to health systems within the state to provide specialized services that help with suicide prevention (e.g., mobile crisis units in New Hampshire). These state and community networks may also help providers and their patients connect with crisis support services, especially because of the nationwide implementation of the 988 number for the National Suicide Prevention Lifeline and SAMHSA’s Mental Health Block Grant program 5% set aside requirement for crisis services.

State Medicaid programs can help reimburse some evidence-based aspects of Zero Suicide (e.g., safety or crisis response planning, care transition programs, peer navigation, follow-up contacts). Procedure codes are already established for some of these activities, but they are not always used in Medicaid contracts with health systems. The COVID-19 pandemic has also made telehealth services more widely available. Establishing state policies to continue allowing and reimbursing the use of telehealth services can extend the reach of suicide prevention within health systems beyond the pandemic.

State surveillance of suicide can be a helpful resource to health systems as they seek to understand the impact that Zero Suicide is having on communities. All 50 states now participate in the National Violent Death Reporting System,^87^ and some states are also participating in the syndromic surveillance system for suicidal ideation and self-directed violence.^88^ Establishing data-sharing agreements with health systems can not only help the health systems evaluate the impact of their suicide prevention efforts (as is being done with some of the case studies discussed in this report), it can also allow states to gather information from the health systems to better understand real-time suicide prevention needs across the state.

Finally, states can enact laws that support suicide prevention among health systems. Two laws were mentioned during case study discussions as having helped support Zero Suicide implementation and sustainability: one required follow-up appointments within 7 days after hospitalizations (Oregon State legislation: ORS 441.054), and the other required practicing clinicians to receive a certain amount of suicide prevention training every few years (Washington state legislation: RCW 43.70.442). These top-down standards and requirements can provide additional scaffolding that supports the long-term sustainability of Zero Suicide within health systems.

## 4.3 National Funders and Decision Makers

Federal agencies like SAMHSA and IHS have already invested a substantial amount of money to help support the implementation of Zero Suicide. The published literature and the experience from the case studies suggest that these agencies, and others like HRSA, can continue to provide valuable financial support to help organizations train providers in suicide prevention best practices; monitor and report on the quality of the suicide prevention practices being implemented; and expand the implementation of Zero Suicide across multiple settings of care within an organization or across partnering organizations.

Government and private health insurance can also play a crucial role in supporting and sustaining Zero Suicide among health systems. Many of the cost benefits from implementing Zero Suicide within a health system are accrued by health insurance companies. Health insurance companies can develop additional reimbursement codes for procedures specifically related to suicide prevention. For example, there are nationally available substance use and alcohol SBIRT procedure codes, but there are currently no suicide SBIRT codes. Suicide SBIRT codes could help fund the use of evidence-based screening tools and evidence-based safety planning or crisis response planning among those who screen positive.

Government and private health insurance can also leverage the mechanisms of ACOs and HVBP to incentivize system-wide changes to prevent suicide. To further use ACOs and HVBP to support suicide prevention, nationally accepted quality metrics related to suicide prevention would need to be established and integrated with these programs.

Finally, national leaders can help support the wider implementation of training in suicide prevention activities among all health care workers. The case studies and literature suggest that the training should not be limited to mental health clinicians, but extend to all clinicians, as the last providers typically seen by patients who die by suicide are not mental health providers.^1^ This training could be integrated within formal training programs of clinicians and health providers. As more providers are trained, they will feel more comfortable and confident in discussing matters related to suicide and following Zero Suicide protocols that are implemented within health systems across the country.

## 4.4 Study Strengths and Weaknesses

Findings from the present study are bolstered by the type and array of data gathered through a literature review, key informant discussions, and case studies of health care organizations that have successfully implemented and sustained Zero Suicide. Case study sites were selected to capture key differences across organizations, resulting in a mix of behavioral health facilities, integrated health systems that offer both physical and behavioral health services, and health systems with multiple or no EHRs. Moreover, each case study comprised semi-structured discussions conducted with staff at different levels of the organization and community partners to represent a wide range of perspectives of Zero Suicide implementation and sustainability.

The study, however, remains subject to limitations in case study selection and implementation. First, the case study sites are not meant to generalize to all organizations enacting Zero Suicide, particularly given the heterogeneity observed in implementation and sustainability. Moreover, it is important to note that the health care organizations included in this study all successfully implemented and are sustaining Zero Suicide. As a result, findings do not include perspectives of organizations who have met with insurmountable challenges related to implementing and sustaining Zero Suicide. This perspective could be an area of future research.

Second, case studies were originally slated to take place via in-person site visits; however, the timing and scope of the COVID-19 pandemic prompted a change to virtual discussions with each case study. The potential loss of in-depth information afforded by in-person visits was mitigated in part by increasing the number of case study sites from five to eight. Additionally, semi-structured virtual discussions were conducted over a longer period of time than the original 2-day in-person visit to prioritize staff availability and reduce burden on sites.

## 4.5 Conclusion

Health systems are positioned to play a crucial role in preventing suicide deaths in our nation because of their contact with many who eventually die by suicide and their access to skilled professionals to help individuals in crisis. However, many providers do not come to an organization trained in or comfortable with discussing suicide risk with patients. Implementing Zero Suicide across a health system empowers providers to be able to identify and address suicide. It establishes clear protocols and practices for providers to identify suicide risk in any setting, address immediate crises, and get an individual into specialized treatment that can improve the patient’s safety, stability, and mental health. It helps avoid hospitalizations and emergency department visits by addressing suicide risk in less intense settings. Sustaining Zero Suicide comes as activities are integrated into daily protocols and work responsibilities, leadership maintains a commitment with people to champion the cause of suicide prevention throughout the health system, results are monitored and shared within and outside the organization, and communities are engaged. In summary, Zero Suicide is sustained with the mentality shared by many of the key informants that “suicide is everyone’s business.”