# 3 Evidence and Experiences from Case Studies

## 3.1 Methods

A list of organizations that have implemented Zero Suicide was compiled through the literature review, discussions with subject-matter experts, and outcome stories available on the Zero Suicide website. Ten organizations were identified and prioritized to capture an ideal balance of behavioral health facilities, integrated health systems that offer both physical and behavioral health services, and integrated health systems without integrated EHRs. Of these ten originally identified organizations, seven opted to participate in the study. After two organizations declined and one had scheduling conflicts that prevented them from participating, an additional organization was identified and contacted to participate, bringing the total number of organizations to eight. These eight organizations are provided below in the order in which they were recruited:

▪ Henry Ford Health System (HFHS).
▪ Centerstone.
▪ AtlantiCare.
▪ Mental Health Center of Greater Manchester (MHCGM).
▪ Kaiser Permanente.
▪ Chickasaw Nation.
▪ Riveredge Hospital and Universal Health Services (UHS).
▪ Avera Health.

To recruit organizations into the study, an email was sent to the Suicide Prevention Coordinator (SPC) or listed contact identified through the organization’s website and outcome stories. This preliminary email included information on the purpose of the study and goals of the case study discussions, the general discussion guide questions (see Appendix B), and how the questions in the guide would vary by types of key informants. We then requested a 30-minute phone conversation to discuss the study in greater detail. If the site staff were willing to participate, a single point of contact was established for identifying the key informants and scheduling discussions.

With input from the point of contact, a list of key informants was developed to have a broad view of the Zero Suicide work done at each organization. It included a mix of leadership, behavioral health providers, other direct care providers, individuals involved in site finance or quality management, and any consultants or committee members who oversaw the implementation of Zero Suicide at the organization. Up to nine total individuals were identified at each site to participate in these informant roles.

The discussions were between 30 minutes and 90 minutes long, depending on the informant’s availability and involvement in Zero Suicide. Leadership and Zero Suicide Coordinators were typically scheduled for 60 minutes or more, whereas providers were more often scheduled for 30 minutes to accommodate their patient schedules. Each discussion guide was tailored to the participant’s role and organization. Because of the COVID-19 pandemic, all discussions occurred virtually over Zoom and WebEx. The discussions were semi-structured, allowing the key informants to diverge at times from the core questions to share the elements of implementation and sustainability that they thought were most relevant and important to share. Discussions included one facilitator, one note-taker, and the participant. Brief notes to guide follow-up questions were taken by the facilitator, whereas in-depth notes were taken by the note-taker during the discussion. Discussions were recorded for note-taking purposes and the recordings were used to follow up on statements that appeared unclear or required more context. Occasionally, materials were mentioned prior to or during the discussions to help place statements in better context. Organizations were asked to provide these materials, if willing, to support or enhance statements made during the discussions.

Each organization’s discussions typically took place within 2 weeks. When the interview was complete, a two-page summary of key findings was written and shared with ASPE which are provided in Appendix A of this report. The notes taken during the discussions were also re-organized by each of the discussion guide questions outlined in Appendix B.

Once all case studies were completed, cross-cutting themes were identified for each of the three main research questions. These themes were identified as each of the analysts reviewed the summary documents and then met together to develop a consensus on the major themes that should be presented in this report. A suicide prevention researcher who did not participate in the discussions but reviewed the summary documents also provided input on the major cross-cutting themes that were evident in the discussion summaries. Additional details regarding the themes were pulled from the notes that had been organized by discussion guide question. The findings on overcoming challenges (RQ3) were integrated with Section 3.2 and Section 3.3.

## 3.2 Implementation Themes

All organizations involved in the case studies had implemented elements of Zero Suicide across all seven of the pillars outlined in the implementation toolkit. The cross-cutting themes presented in this section are intended to supplement and not reiterate the content provided in the toolkit. We found themes related to early adoption, ongoing implementation, and growth of Zero Suicide, as outlined in Figure 1. We describe these themes and how they relate to the different pillars of Zero Suicide in the following subsections.

Figure 1 Implementation Themes across Case Study Sites

FIGURE 1, Flow Chart: Early Adoption--(1) Garnering critical mass to support adoption and implementation at the system or organizational level. (2) Gathering resources and information prior to or in conjunction with early implementation. (3) Establishing champions and dedicated staff. Implementation--(1) Achieving staff buy-in through culture and workflow. (2) Standardizing practice through guidelines and protocols. Growth--(1) Cultivating new or leveraging existing community partnerships. (2) Forging avenues for continuous monitoring and quality improvement. Pillars of Zero Suicide--Lead, Train, Identify, Engage, Treat, Transition, Improve.

### 3.2.1 Early Adoption

Garnering critical mass to support adoption and implementation of Zero Suicide at the system or organization-level. All case study organizations described initial commitments made by key senior leadership that marked a prerequisite for the early adoption and funding of Zero Suicide. Support was provided by a range of players across sites, including health systems CEOs, regional leaders, and senior behavioral health staff. These key staff commitments essentially served to greenlight the system-wide culture change committed to reducing suicides comprising LEAD, the first pillar of Zero Suicide implementation.

Organizational Fit

The Zero Suicide initiative integrated with other organizational goals such as quality improvement, establishing a high-reliability organization, participating in an ACO, primary care behavioral health integration, SBIRT, or designing a system to support zero medical errors.

The organizations commonly emphasized that Zero Suicide was, and is, in alignment with system-level or organization-level goals. However, the way in which Zero Suicide was perceived to fit into the organization was, in part, dependent on previous or ongoing initiatives that varied from organization to organization, such as behavioral health integration, accountable care, and quality improvement. For example, one organization cited its earlier transition to integrated care--and the resulting teams-based approach--as a critical precursor to Zero Suicide implementation. For another organization, primary care clinics had already laid the groundwork for conducting patient screens and follow-up through SBIRT and were, therefore, better prepared to incorporate suicide prevention practices in those same settings.

Gathering resources and information prior to or in conjunction with early implementation. Case study organizations obtained preliminary information about Zero Suicide through a combination of formal and informal means. For example, four of the eight health care organizations elected to have staff participate in the Education Development Center’s 2-day Zero Suicide Academy workshop, which provides training on the Zero Suicide framework and approaches to implementation to health and behavioral health care teams.^83^ These trainings were most often held at an external location and were attended by select staff, but one organization elected for it to take place on site to accommodate attendance by a greater number of staff members. Other sites navigated early implementation with the assistance of a mentoring organization or agency with expertise in successfully implementing and sustaining Zero Suicide, although the degree and length of this mentoring varied from organization to organization.

Workforce Survey

Several organizations found it beneficial to do an initial workforce survey to understand the skills and confidence of providers in suicide prevention. One organization said that it was surprising to find out that 50% of its inpatient behavioral health staff felt uncomfortable talking about suicide with a patient. This finding highlighted the need to train and support staff in suicide prevention efforts.

Information-gathering was a precursor to TRAIN, the second pillar of Zero Suicide implementation. As organizations learned about Zero Suicide and their workforce attitudes and skills regarding suicide prevention, they were able to make informed decisions regarding the types of training to offer (e.g., B-CBT, CBT-SP, counseling on access to lethal means); the structure of the training (e.g., multi-day workshops, online); and the model (e.g., train-the-trainer, end users).

Implementation decisions were also influenced by cost considerations, previously established protocols within the health system, and the evidence base for different trainings. For example, many organizations used the PHQ to screen for suicidal thoughts because this was already being used within some settings of their health system. Other organizations used the C-SSRS screening and assessment tools because of the evidence regarding their validity and reliability.^84^ One organization, however, implemented the Assessing and Managing Suicide Risk (AMSR) assessment approach^85^ to evaluate its validity and reliability.

Gathering Data on Suicide

One organization worked with its state violent death reporting system to better understand which of its patients were dying by suicide. It found that about 60% of suicide deaths were among patients not receiving mental health services. This finding encouraged the organization to implement Zero Suicide across all settings of their organization to better identify and help all individuals at increased risk of suicide.

Establishing champions and dedicated staff. All organizations created or identified suicide prevention steering committees to meet on a regular basis during implementation of Zero Suicide. At some sites, the committee was interdepartmental, capturing a range of perspectives in and across groups such as behavioral health providers, quantitative researchers, and senior leadership. At others, the committee consisted primarily of the behavioral health staff tasked with implementing Zero Suicide. Although some sites enacted Zero Suicide activities using existing staff, roughly half established new staff positions to facilitate key tasks, including patient-tracking and outreach and care coordination (e.g., peer specialist to provide Caring Contacts).

Staff involvement in the steering committee and related Zero Suicide activities was largely informed by the overall organizational structure and applicable service line settings (e.g., behavioral health, primary care, inpatient care). Indeed, the approach to rolling out Zero Suicide varied across systems--some organizations began implementing Zero Suicide in select service lines (e.g., behavioral health services) before expanding to other settings, whereas others rolled out implementation in all service lines at once. The staff type and level of involvement differed in and across organizations over time accordingly.

In summary, implementation themes around early adoption of Zero Suicide provide additional insight into the process of building up the pillars of LEAD and TRAIN through support from key leadership, information and resource gathering, and dedicated staff involvement. Although the specific approaches to early adoption varied across organizations, commonalities were identified within each theme. Namely, all organizations described initial commitments from key senior leadership as a prerequisite for next stages of adoption and implementations of Zero Suicide. Each organization obtained preliminary information around Zero Suicide through a combination of workshops, trainings, and workforce surveys to determine subsequent aspects of implementation. Additionally, all organizations created or identified suicide prevention steering committees to facilitate implementation.

### 3.2.2 Ongoing Implementation

Achieving staff buy-in through culture and workflow. A common goal across organizations was cultivating staff buy-in around the mission and activities comprising Zero Suicide. Leadership determined the strategies used to accomplish staff buy-in, including the following:

▪ Aspirational messaging. At several sites, care was taken to communicate that achieving zero suicide deaths is an aspirational goal meant to underscore the importance of quality in care and prevention across primary and behavioral health settings alike. Organizations also presented the idea that zero is the only acceptable number of suicide deaths that should be allowed within an organization. For one site, Zero Suicide was framed as achieving zero defects in care for patients at risk of suicide; at another, the strive for zero suicide deaths was compared to the strive for zero medical errors.
▪ Organizational identity. In addition to fostering individual staff’s understanding and support of Zero Suicide, sites described an underlying shift in organizational identity intended to promote a sense of unity in and shared responsibility for suicide prevention. Statements like “this is what we do” and calls to both ethical duty and broader initiatives were described as points of emphasis to staff members “from day one” of hire.

Challenge: Provider Resistance

Zero Suicide pillars affected: LEAD and TRAIN.

A commonly reported hurdle across health care organizations--particularly those with integrated behavioral health--was initial resistance to Zero Suicide on the part of providers. The speculated reasons behind this response varied, from discomfort in discussing suicide with patients to, in the case of primary care providers, a previous lack of accountability for identifying mental health issues, particularly if the presenting reason for the visit was physical in nature.

All organizations took these concerns seriously, and took steps to ensure the following:

▪ Suicide prevention training engendered a sense of ease when talking about and responding to suicide risk.
▪ Primary care providers were encouraged to consider health holistically.
▪ Quality assurance measures and EHR safeguards were used to track and facilitate adherence to protocols.

In turn, organizations reported unforeseen positive impacts from suicide prevention training, such that providers gained a greater ability to have meaningful dialogue with patients and thus provide higher-quality care.

▪ Process-oriented changes to workflow. At several sites, changes to clinical workflow and infrastructure were made to facilitate implementation of Zero Suicide and to act as a safeguard against user error or nonadherence to Zero Suicide protocols. In some cases, these changes came in the form of dedicated staff positions (e.g., SPC) or internal support from existing staff (e.g., quality improvement, information technology). In others, the EHR was customized to promote fidelity to Zero Suicide, although the extent of customization was subject to EHR capabilities and staff availability. For example, at roughly half of sites with EHRs, developments included automated processes such as online screenings and scoring, assessment templates, and designation of patients identified as at-risk or on the suicide prevention pathway. At the remaining sites, EHRs were primarily used to extract relevant data (e.g., manually entered screening results, provider notes) to electronic dashboards. Another common feature integrated in EHRs and external dashboards was a color-coded record to indicate a patient’s risk stratification or placement on the suicide prevention pathway so that all providers who interacted with the patient were made aware of their risk status.

The Joint Commission Standards for Suicide Prevention

Health care organizations that are accredited by the Joint Commission must meet required standards in various aspects of patient care, including suicide prevention.^86^ At some sites, citing the Joint Commission’s requirements for assessing and addressing suicide risk helped facilitate the implementation and sustainability of Zero Suicide. Sites that had already implemented protocols were faced with additional costs and resources as they tried to adjust and align what they had done with what was being required.

Standardizing practice through guidelines and protocols. In addition to establishing a system-wide culture in which to enact suicide prevention practices, organizations cited standardized guidelines and protocols as key to embedding Zero Suicide activities in everyday practice, thus creating a foundation for pillars to IDENTIFY, ENGAGE, and TREAT. Although the settings in which Zero Suicide was implemented differed from site to site, based in part on services offered and population being served, sites frequently emphasized the need for uniformity in how screenings and crisis services were delivered within each setting. For example, suicide-risk screenings were incorporated at the beginning of every patient visit at all sites, with protocols tailored for specific patient populations and harmonized across participating primary and emergency settings as applicable. Notably, the strategies carried out to attain consistency across providers and settings varied by site. At one organization, screening protocols were printed out on mousepads to serve as reference; at others, EHRs were used to assist providers with screening and any requisite care coordination and patient follow-ups. As another example, screenings and crisis services with youth populations--be it in a medical or school-based setting--included hands-on activities and parent or guardian involvement in safety planning and treatment.

In summary, ongoing implementation of Zero Suicide is characterized, in part, by efforts to establish and embed Zero Suicide activities in everyday practices to facilitate pillars to IDENTIFY, ENGAGE, and TREAT patients. These efforts are primarily focused on necessary changes to staff culture and clinical workflow. Namely, organizations enact strategies including aspirational messaging, shifts to organizational identity, and process-oriented changes to workflow to cultivate staff buy-in around Zero Suicide. A key challenge in this process is provider resistance, especially in the case of primary care providers who may not have the requisite training in mental health and suicide prevention. In response, organizations can provide suicide prevention training and encourage a holistic perspective toward health, with additional safeguards provided by quality assurance and EHR processes. Organizations also consider standardized guidelines and protocols as especially important to codify necessary shifts to workflow in and across patient populations.

### 3.2.3 Growth

Partnering to Offer Follow-Up Calls versus Other Alternatives

Organizations enacted different approaches to follow-up calls to patients. Partnerships with pre-existing call centers reduced expenditures for the health systems, but they also created some additional challenges with information sharing. Follow-up calls by providers strengthened their rapport with patients, but they sometimes resulted in longer conversations that were not always billable. Some organizations tried to be more cost efficient by having designated staff or internal call centers provide follow-up calls to their patients.

Cultivating new or leveraging existing community partnerships. Community partnerships were used to support implementation activities and expand outreach to additional populations at most case study organizations. Roughly half of these partnerships were developed to fill a specific need in implementation, such as patient-tracking and contacts, afterhours care, and crisis calls. Other partners were used as a connecting force to share resources to enact quality suicide prevention care across wider service areas. For example, one health care organization participated in a coalition with an entity with state-based funding, and many volunteers available to build community awareness, training, and outreach. Other community organizations were used for similar purposes of education and outreach, including school-based programs, faith-based institutions, and law enforcement programs.

Forging avenues for continuous monitoring and quality improvement. All sites recognized that implementing Zero Suicide is an ongoing process, with room and encouragement for continuously adapting approaches to meet the needs of the patient population. To that end, sites enacted regular audits and accountability checks to ensure fidelity to Zero Suicide protocols and post-incident reviews when needed. The specific nature of audits varied, from general chart reviews to more-intensive examination of enrollment processes and trends (e.g., provider-specific activity in overriding automatic enrollment recommendations). Additionally, conversations among providers and administrators were viewed as an ongoing opportunity to identify and resolve any issues in communication or workflow.

Through monitoring efforts, some sites noticed lower-than-desired rates of suicide screening and follow-up assessments. As a result, sites worked to change their EHRs to include automatic reminders for filling out the screeners and follow-up assessments. One site also started to implement an online suicide screening tool, sending it to patients up to 48 hours prior to their appointment. Another organization partnered with an independent company called Tridiuum to ensure broader delivery of behavioral health screening and assessment. These organizations experienced initial improvements in the prevalence of screening and follow-up assessments, and they continue to monitor their growth in this area.

Challenge: Sharing and Tracking Health Records

Some organizations used multiple EHRs within their system, and one organization used only paper records. This lack of integration made it hard to share and track records and often created silos of information. To address these challenges, organizations created centralized suicide prevention dashboards or shared documents that pulled information across the different EHRs. These documents and dashboards provided summary statistics on process and outcome measures and helped track the individuals who were on the suicide prevention treatment pathway. With paper records, standard forms were created and protocols were established for summarizing and sharing information at each patient or provider transition.

Implementation themes around growth are best understood in relation to pillars to TRANSITION and IMPROVE Zero Suicide in and across organizations. Organizations leverage community partnerships to carry out specific aspects of implementation, expand reach of suicide prevention practices to wider service areas, or provide further education and outreach to the community. Additionally, sites incorporate internal checks to ensure that Zero Suicide protocols are maintained, or improved, so that the needs of the patient population are met. These checks generally include regular audits and post-incident reviews and continued communication among providers and administrators alike. Information sharing also poses a challenge in practice, however, dashboards and centralized documents for tracking key outcomes can help identify areas for growth and improvement.

## 3.3 Sustainability Themes

Organizations shared that the decision to implement and sustain Zero Suicide was founded to save lives and improve the quality of care, not to save money. Many of the organizations provided substantial internal funding to implement Zero Suicide and train staff; however, they also described the ongoing maintenance costs of Zero Suicide as minimal. Some elements of Zero Suicide were described as being low-cost but having a high impact. Over time, all the organizations in the case studies diversified their funding of Zero Suicide through a variety of external funding opportunities. The organizations have also seen that their investments in Zero Suicide helped offset other costs of care for patients.

Some providers and leaders expressed that a greater concern than financial sustainability was sustaining fidelity to their implemented Zero Suicide protocols and practices. This concern is one of the major purposes behind the IMPROVE pillar of Zero Suicide. Organizations mentioned that monitoring and sharing success stories was crucial to sustaining the work. Strategic community partners were also an important part to sustaining the work of Zero Suicide and making it part of the community’s identity and not just part of the organization’s identity.

### 3.3.1 Internal Funding

A common theme across all case studies was that they had senior leadership buy-in to support internal funding for Zero Suicide. Some of the larger organizations had to actively seek out a senior level sponsor within the organization, whereas a few of the others had a member of the executive leadership team involved from the beginning. Organizations that spanned multiple states received additional resources and financial support, as they engaged both regional-level and national-level leaders within their organizations.

Where possible, senior leadership and those who championed for Zero Suicide throughout the organization encouraged integration of suicide prevention practices into standard workflows to minimize the need for additional costs. This approach was particularly evident within the inpatient setting, where staff are salaried and do not typically get paid differently for offering more or different services. Zero Suicide meetings and trainings were also integrated with pre-existing staff meetings when possible. One organization gives their patients an annual allotment for taking time off from work to do trainings. Zero Suicide training was offered within this annual allotment. Because of the integration of Zero Suicide with standard practice, none of organizations said they had a specific line item in their budgets for Zero Suicide.

Rather than functioning with a budget around Zero Suicide, most organizations approached investments on an as-needed basis. These one-time approvals were typically for larger expenses, like training costs, EHR modifications, or hiring a staff member to help with a specific aspect of Zero Suicide (e.g., SPC or someone to offer follow-up calls). Some organizations also had internal grant mechanisms that were leveraged to help in the initial implementation of Zero Suicide.

### 3.3.2 External Funding

Although all the case studies started implementing Zero Suicide through internal investments, all but one have since sought external funding opportunities. In many instances, it was because of the initial progress they made through internal investments that better qualified them to win external funding to support their ongoing efforts.

One major finding was that using procedure codes to get claims-based reimbursement for Zero Suicide activities was mostly limited to when suicidal individuals received clinical evaluations and psychotherapy services (see Table 1). Organizations said that they typically did not bill for suicide risk screening unless it was done as part of an independent assessment or an evaluation with a provider present (e.g., procedure codes 90791, 90792, 99201-99215). Many of the organizations said that the screening procedure codes listed in Table 1 (96127, G0444, G8431, G8510) were not in their contracts or were not reimbursed. Once a patient was identified and received a diagnosis, suicide-specific psychotherapy services were covered and reimbursed, and an add-on code (90785) was sometimes used to increase reimbursement because of the added complexity of the situation. Only one organization specifically said that it used the collaborative care management and chronic care management procedure codes to support its Zero Suicide activities; however, another organization said that it was exploring ways to reimburse follow-up engagement services through case management procedure codes and billing. As a standard practice, many of the health systems had designated staff to help uninsured patients become insured. Once they were insured, the health systems could be reimbursed for at least the evaluation and counseling sessions.

Many of the external funds and supports came through partnerships with states. Some states had received grants to fund a crisis call center, and the health care organizations partnered with those call centers to offer follow-up calls. Some states received Centers for Medicare & Medicaid Services demonstration waivers to pay for unique services that helped pay for elements of Zero Suicide (e.g., care transitions). One state also funded a health care organization’s mobile crisis unit to help reduce the burden on emergency departments and the long wait times of patients experiencing a mental health crisis.

Table 1 Number of Organizations Using Different Procedure Codes to Reimburse Zero Suicide Activities

Procedure Codes | Used to Reimburse Zero Suicide Activities?
Procedure Codes | Yes | No
96127, G0444: Administration, scoring, and documentation of a brief behavioral or emotional screening instrument | 1 | 5
G8431: Screening for depression is documented as being positive, and a follow-up plan is documented | 0 | 6
G8510: Screening for clinical depression is documented as being negative, and a follow-up plan is not required | 0 | 6
90791: Psychiatric diagnostic evaluation (without medical services) | 6 | 0
90792: Psychiatric diagnostic evaluation (with medical services) | 4 | 2
99201–99215: Office or other outpatient visit for the evaluation of a new or established patient | 6 | 0
90832, 90834, 90837: Individual psychotherapy 30, 45, and 60 minutes | 6 | 0
90839, 90840: Psychotherapy for crisis, for first 60 minutes + crisis code add-on for each additional 30 minutes | 5 | 1
99492, 99493, 99494, G0502, G0503, G0504: Psychiatric collaborative care management | 1 | 5
99490, 99491, 99487, 99489, G0506: Chronic care management services | 1 | 5
90785: Add-on codes for complexity (may be reported as appropriate with 90791, 90792, 90832, 90833, 90894, 90896, 90853, 90837, 99201-99255, 9930-99337, and 99341-99350) | 5 | 1

Note: These procedure codes were identified from the Financing Suicide Prevention in Health Care Systems: Best Practices and Recommendations^2^ and the Safer Suicide Care Billing Tip Sheet.^72^ One organization also mentioned the use of the CPT codes: 3351F, 352F, 3353F, and 3354F--diagnostic/screening processes or results. Another organization mentioned the use of other therapy and evaluation codes (90853, 90846, 90847, 99354, 99355, 99417, G2212, 90833, 90838) and other phone and telehealth codes (99441-99443, 98966-98968, 98970-98972) for delivering care that supported its Zero Suicide activities. Reimbursement based on specific procedure codes was not applicable to two organizations that, as a result, were excluded from this table.

Many of the organizations pursued federal grants to fund different aspects of their work. SAMHSA grants related to suicide prevention during the COVID-19 pandemic were pursued to help support the monitoring and delivery of suicide prevention services that they had already been implementing and wanted to expand. SAMHSA SBIRT grants helped establish resources in primary care clinics for doing screening and follow-up, which set the stage for doing additional screenings and follow-up related to suicide. One organization is the recipient of a grant with NIMH that is helping to fund an evaluation of their Zero Suicide work. Two organizations leveraged support through HRSA grants. One organization received a grant through the HRSA Evidence-Based Tele-Behavioral Health Network Program to help fund behavioral health counseling and crisis assessment services in rural areas. The other organization partnered with a local university that had received a behavioral health nursing education grant, and part of the grant funds helped support a state-wide conference to inform nurses and health care providers about Zero Suicide. Only two of the eight organizations were recipients of a specific SAMHSA Zero Suicide grant, and at least one received funding from SAMHSA to attend a Zero Suicide Academy.

Some support was also achieved through community partnerships. One organization partnered with local emergency departments to be reimbursed for providing assessment and follow-up for suicidal patients. Two organizations partnered with the National Alliance on Mental Illness (NAMI), one to engage peer specialists in their Zero Suicide activities and another to help train staff on recognizing and addressing suicide risk. As one organization has become an expert in offering dialectical behavior therapy (DBT) for treating mental illness and preventing suicide, other local health care organizations have paid them to do clinical trainings.

Finally, two organizations helped sustain Zero Suicide through philanthropic efforts. One organization received philanthropic support to help pay for some staff training and is seeking to establish an endowed chair in suicide prevention research. Another organization has an annual fundraiser to increase awareness of mental health problems in the community and to help pay for a peer navigator who offers follow-up support to patients at increased risk of suicide.

### 3.3.3 Start-Up and Ongoing Costs

Organizations said the largest start-up costs were for training staff and making changes to the EHR. Training staff included an initial organization-wide event to introduce the concepts of Zero Suicide and the purpose of the initiative (e.g., Zero Suicide Academy for the organization); training for screening and identifying individuals at risk of suicide (e.g., C-SSRS, AMSR); training on how to help keep suicidal patients safe (e.g., safety planning, crisis response planning, counseling on access to lethal means); and training for suicide-specific therapies (B-CBT, CBT-SP, DBT). To help minimize costs of training, all organizations either used a train-the-trainer approach--wherein a few staff received training to be able to teach the skills to other staff--or they created an online version of the training. One organization has invested substantial internal funds to develop an online dynamic training platform that uses patient simulations and other interactive features to train staff. It is designed to be used at flexible times to minimize lost earnings from taking a provider out of the clinic, and it is estimated to cost only a third of the price of typical in-person trainings.

EHR Modifications

Establishing forms and reminders in the EHR helped organizations sustain fidelity to Zero Suicide activities. These changes to the EHR included the following:

▪ Attaching forms for screeners and automatic follow-up screeners or safety planning templates when an individual screens positive for increased suicide risk.
▪ Color-coding records for patients who are on a suicide treatment pathway.
▪ Indicating in a prominent location on the EHR whether the person has had a recent suicide attempt.

Although customizations to EHRs are an ongoing practice for health care organizations, the organizations said they had to work to get the changes for Zero Suicide prioritized above other changes. These changes cost substantial time and money, not only to implement, but also for providers to learn to use them. Still, these changes were mentioned as being a critical step to sustaining Zero Suicide through integrating practices into the workflow and monitoring progress. Some of the EHR customizations included approaches to documenting and tracking the completion of screenings and safety plans, or alerting features (e.g., color-coding) of high-risk or suicidal patients so that all providers seeing the record know when an individual needs extra suicide prevention care.

Implementing Zero Suicide also included some administrative costs. These costs included the establishment of a Zero Suicide committee to help make decisions and sustain the implementation of Zero Suicide. Organizations suggested that these committees be multidisciplinary from across the layers and locations of the organization, and that they have the involvement of someone senior enough to get financial buy-in from the executive team. The Zero Suicide committee acts as a central hub for developing and reviewing protocols and practices, and then disseminating those through staff meetings.

Challenge: Coordination

Organizations shared that, when Zero Suicide is first implemented, there are many different assignments and activities. They suggested that a program manager be identified from the beginning who could help coordinate and keep track of all these activities.

For some organizations, the Zero Suicide committee was an ongoing cost; however, at least one organization discontinued the committee after several years of implementation. That organization still had specific staff that were devoted to overseeing and implementing Zero Suicide. Six organizations had an existing staff member assume suicide prevention coordination as part of their role, whereas the remaining two organizations hired a new staff member to be a SPC. A few of the organizations hired someone specifically to help provide follow-up and engagement calls with patients leaving a psychiatric inpatient unit or who are in crisis. Some new-hires were designed to help with suicide prevention in the context of broader mental health initiatives, such as providers to help with primary care mental health integration and peer-support specialists.

Challenge: Staff Turnover

Staff turnover results in ongoing training needs for the organization. It is particularly challenging when a staff member who leads suicide prevention trainings leaves the organization. Organizations suggested investing in several trainers throughout the organization to be able to compensate for setbacks in staff turnover.

Ongoing training costs were typically integrated with new staff orientation. Booster sessions were also integrated on an as-needed basis with staff meetings. One challenge that organizations experienced was staff turnover of trained staff. One organization offered a booster session for several of its outpatient providers but did it on a weekend to avoid lost earnings from taking providers out of the clinic.

Ongoing activities associated with oversight and monitoring of Zero Suicide were typically not seen as additional costs to standard practice. For example, auditing of medical records takes place irrespective of Zero Suicide implementation, and all the organizations mentioned auditing and performance reviews as a way in which they check to see whether Zero Suicide protocols are being followed.

Sites were asked to share what the low-cost, high-impact Zero Suicide activities are. The three activities that were consistently shared are screening, safety or crisis response planning, and follow-up calls. Even if these activities are not fully integrated with the EHR, they can be implemented with little cost to the organization. Proper safety planning does require training, but there are apps being developed and training modules that organizations have created to help staff learn how to safety plan with patients who screen positive for suicidal ideation or a recent suicide attempt. A quick follow-up call can be done when an at-risk patient misses an appointment or after they are discharged from a hospital. These follow-up calls do not need to be done by the provider; they can be done by junior-level staff or interns when a clear protocol is in place. One organization found that it was more efficient to have someone from intake and assessment, rather than the provider, follow-up after hospitalizations, especially when that person briefly meets the patient prior to discharge and is familiar with the patient’s safety plan and discharge plan.

Overall, many of the ongoing costs of Zero Suicide can be paid for in the normal course of business, and those that cannot are typically low-cost with high potential impact for helping clients at risk of suicide. Screening may not be reimbursed, but it can help identify individuals in need of treatment, and once the individual starts receiving treatment, those treatment services are reimbursed. More telehealth being reimbursed has allowed for more-timely virtual follow-up appointments with patients who are at increased risk of suicide. The ongoing monitoring, training, and oversight of Zero Suicide is typically integrated with pre-existing practices and staff meetings so that any additional costs are minimal. The area where organizations have made the largest investments because of their commitment to preventing suicide is the one-time start-up costs related to training and EHR modifications.

### 3.3.4 Potential for Cost Offsets

No rigorous return on investment study has been done for Zero Suicide as a whole; however, two organizations said they were planning on doing a comprehensive cost study, and many of the organizations found potential cost offsets from implementing Zero Suicide (see Appendix A and citations below):

▪ Readmission rates were reduced by 17%-21% following the implementation of Zero Suicide.
▪ Rehospitalization among patients with suicidal ideation decreased by 45%.
▪ Care transition teams reduced emergency department visits by 70% and hospital bed days by 90%.
▪ Mobile crisis teams diverted 94% of clients away from emergency departments.
▪ Diverting suicidal patients away from the inpatient setting and being able to address suicidality in the community saved an estimated $200,000 per year.^76^
▪ Enhanced crisis follow-up to patients discharged from the emergency department saved approximately $2.7 million from prevented psychiatric hospitalizations and rehospitalizations for suicide (see Appendix C for additional details).
▪ Overall expenses for the mental health division were reduced by $3.5 million over 3 years.^20^

Organizations expected to see reductions in emergency department visits and hospitalizations because Zero Suicide protocols allowed providers to recognize challenges earlier and address them in an outpatient setting. Some providers have seen fewer outpatient visits once suicide risk is identified and addressed, particularly when suicide prevention and other behavioral health services are integrated within primary care. Finally, effective ENGAGE protocols for Zero Suicide have helped reduce the number of missed appointments, thereby increasing provider productivity and earnings.

Some leaders and providers said that the publicity received by organizations around suicide and suicide prevention has impacted their costs and earnings. One organization experienced significant negative publicity for the high-profile suicide death of one of its patients. This event, and its significant cost repercussions, was used to encourage senior leaders in the organization to invest in implementing Zero Suicide to reduce overall suicide risk and the related liability concerns associated with suicide deaths. As organizations have implemented Zero Suicide, they have also received positive attention from their communities and have been recognized as leaders in suicide prevention efforts by local governments and other health care organizations. They believe this positive publicity has brought greater revenue and patient satisfaction.

One challenge with these cost offsets is that they do not always fully benefit the organizations offering the interventions. For example, outpatient behavioral health organizations do not financially benefit from reducing hospitalizations unless they are part of a larger integrated health care system that offers both levels of care. Some organizations have tried to work with health insurance companies to agree to reimburse promising practices that are being implemented as a part of Zero Suicide (e.g., follow-up services for emergency department visits). Other organizations have joined ACOs to be able to establish shared cost savings across different settings.

ACOs and HVBP

There is an opportunity to establish more financial incentives for suicide prevention through ACOs and HVBP. To do this, organizations said that uniform suicide-related quality measures need to be established and adopted within the federal programs.

Some providers shared that they viewed Zero Suicide as having a greater likelihood of being cost neutral than cost saving for an organization. They acknowledged that, although there are potential cost offsets, there are also increased expenditures that come with identifying and treating more health care needs and training staff to deliver this additional treatment. More research needs to be done to understand how the cost offsets balance with the cost increases.

### 3.3.5 Sustaining Fidelity

All eight organizations reported a culture shift around preventing suicide, and they shared that suicide prevention had become an integrated part of what they do. Despite this integration, some leaders still expressed concern about sustaining and maintaining fidelity to the protocols and practices that had been integrated with their workflows.

Challenge: Time for Safety Planning

Some providers struggled to have enough time to create a thorough safety plan, especially when suicidal thoughts were not shared until later in a session. One organization allows providers to create an abbreviated version of the safety plan if the patient is lower risk. This abbreviated version focuses more on suicidal thoughts, keeping the environment safe, and establishing safety contacts. A complete safety plan is then created during the next available session.

Monitoring practices and outcomes was mentioned across all organizations to help sustain fidelity. Each organization had its own unique set of process measures (see Appendix D); however, there were commonalities: they all tracked whether an initial screening was done and whether follow-up actions were taken among those who screened positive. Organizations also typically track follow-up calls and the creation of safety plans or CRPs. Tracking the quality of these calls and plans has been challenging. To help with the quality of follow-up calls and outreach, organizations set up clear protocols for their staff to follow (see examples in Appendix E). Organizations are still trying to develop efficient ways to track the content and completeness of safety plans and CRPs. Some have specific sections in the EHR where safety plans are recorded in detail, whereas others develop a plan on paper and then upload an image to the medical record, which can be harder to track completeness.

One approach to monitoring used by all organizations is conducting regular chart reviews and workforce surveys. In these reviews, leaders can evaluate in greater detail the Zero Suicide practices and the quality of the safety plans and other activities related to engagement and treatment. In addition to these regular audits, some organizations chose to do follow-up workforce surveys to understand providers’ ongoing confidence and commitment to following Zero Suicide practices (https://zerosuicide.edc.org/resources/resource-database/zero-suicide-workforce-survey-resources). These follow-up surveys allow the organization to track improvement over time and to identify where there still are needs or concerns. When organizations identify systematic problems through audits or surveys, they work with the provider or entire unit to provide additional training and support.

Many organizations sought to track outcomes related to suicide and suicide attempts; however, they said it was difficult to capture a complete and accurate picture of all suicide-related outcomes, as many occur outside of their health systems. Integrated health systems were able to track suicide-related hospitalizations and emergency department visits more easily than outpatient behavioral health organizations were, although one organization mentioned that providers in the emergency department and inpatient settings do not consistently code suicide attempts in the medical records. To address this challenge, they started to train emergency department and inpatient providers about proper coding techniques for suicide-related behaviors. Other organizations have partnered with community surveillance efforts to help track suicide attempts and deaths that happen in the community. One outpatient organization, for example, worked with its state hospital association to gather better data on suicide-related hospitalizations. Two other organizations linked their patient records with state death records to identify those who died by suicide. These efforts have improved the organization’s ability to track the impact it is having on preventing suicide over time.

Providers said that something that helped sustain their involvement in Zero Suicide activities was hearing success stories and seeing outcome metrics. One organization would regularly post metrics for units to see how it was doing with its participation in Zero Suicide activities. Other organizations established electronic dashboards and sent weekly reports to unit leaders on how the unit is performing and which patients are being flagged at increased risk of suicide. Many of the success stories came from the follow-up calls that were done with patients. One organization shared the experience of following up with a patient who missed an appointment and finding out that the patient was on a bridge thinking about suicide. Because of the follow-up call, the organization helped the patient step away from the bridge and got police to escort the patient to safety and treatment. Although these life-saving experiences may not happen with great frequency, they have a powerful impact on motivating the continued efforts of the Zero Suicide initiative within an organization.

Another way to facilitate sustained involvement in Zero Suicide was to incorporate individuals with experience related to suicide loss in the decision making process. Many of the organizations included survivors of suicide loss as a part of their Zero Suicide committees. One organization also encouraged leaders to share their personal experiences with exposure to suicide loss. This vulnerability among the leaders of the organization helped other providers be willing to share their lived experience related to suicide, thus expanding the dialogue and commitment to prevent future suicide deaths.

Finally, establishing a network of community partnerships has helped sustain the Zero Suicide efforts of many of the organizations. One organization partnered with its local fire and police departments to establish a comprehensive mobile crisis team, and the fire and police departments also rely on the organization to do their Crisis Intervention Team trainings. Two organizations have established close relationships with local hotlines to offer follow-up calls. One organization has been heavily involved in the state suicide prevention network, offering training on Zero Suicide throughout the state. Another organization has also helped establish a state-wide gathering for health systems to learn about and discuss suicide prevention. Multiple organizations are trying to establish a network of Zero Suicide health systems, providers, and community services so that suicide prevention becomes part of the entire community’s identity. This peer-support within communities is helping maintain momentum and fidelity to Zero Suicide protocols and practices.