# 2 Evidence from the Literature

## 2.1 Methods

The following key words were searched in pubmed.gov, Google Scholar, and general internet search engines: Zero Suicide, suicide prevention, health care systems, suicide, suicide intervention, health systems, vision zero. A snowball method was also adopted to identify material related to Zero Suicide, beginning with HFHS publications^10,20^ and reports from the Zero Suicide Institute websites (e.g., zerosuicide.sprc.org, zerosuicideinstitute.com). Four subject-matter experts (Brian Ahmedani of Henry Ford Health, Julie Goldstein Grumet of the Education Development Center, Barbara Stanley of Columbia University, and Virna Little of the City University of New York) were also consulted to learn of any published or unpublished articles and presentations related to the implementation and sustainability of Zero Suicide.

## 2.2 Implementing Zero Suicide

Zero Suicide for health care systems was defined in the literature as a system-level or organization-level approach to directly address suicidal behaviors, to continually improve the quality and safety of care processes, and to strive for the aspirational goal of zero suicide deaths.^21^ A Zero Suicide Toolkit was developed by the Suicide Prevention Resource Center to guide health care systems in implementing this approach and initiative (https://zerosuicide.sprc.org/toolkit). The toolkit outlines seven categories of activities, or “pillars” for preventing suicide within a health care system:^22^

1. LEAD system-wide culture change committed to reducing suicides.
2. TRAIN a competent, confident, and caring workforce.
3. IDENTIFY individuals at risk of suicide via comprehensive screening and assessment.
4. ENGAGE all individuals at risk of suicide using a suicide care management plan.
5. TREAT suicidal thoughts and behaviors using evidence-based treatments.
6. TRANSITION individuals through care with warm hand-offs and supportive contacts.
7. IMPROVE policies and procedures through continuous quality improvement.

Additional materials were also found in the literature that show how Zero Suicide can be operationalized within a health care organization. For example, HFHS has developed detailed Zero Suicide Prevention Guidelines that are publicly available.^23^ Stanley and colleagues also developed the Assess, Intervene, and Monitor for Suicide Prevention (AIM-SP) model as a guide for implementing Zero Suicide in New York outpatient clinics.^17,24,25^

### 2.2.1 Experiences Implementing Zero Suicide

Two organizations that helped test the implementation of the Zero Suicide Toolkit were Centerstone, a large behavioral health nonprofit that implemented Zero Suicide at its locations in Tennessee and Indiana, and the Institute for Family Health in New York.^13^ These organizations reported high adoption of the protocol. Within the first 2 years of beginning Zero Suicide work, Centerstone initially saw a 64% reduction in suicide rate from October 2012 to April 2015 among its patients.^13^ This rate has slightly fluctuated throughout the years.

At the time this report was written, two large implementation and effectiveness studies on Zero Suicide are being conducted in the United States. One is with approximately 200 licensed freestanding or state-operated mental health clinics in New York and is expected to conclude in 2021.^17,25^ It uses the AIM SP model to guide its implementation approach and is tracking protocol adoption, implementation barriers and facilitators, and outcomes such as suicidal behaviors, hospitalizations, and emergency department visits. The other is a 5-year study involving the HFHS and several Kaiser Permanente sites across the country that is expected to end in 2022.^16,26^ This study is investigating suicide attempt and mortality outcomes across the multiple health systems. Thus far, both studies have found large variability in how Zero Suicide is practiced within each participating site. For example, the sites differ in the screening tools they use, in their levels of behavioral health and primary care integration, in the suicide-specific treatments they offer, and in the type and frequency of follow-up contacts after hospitalizations or emergency department visits.

The Suicide Prevention Resource Center has also developed several Zero Suicide Outcome Stories that provide examples of how organizations have implemented Zero Suicide and the practice-based evidence that they have begun to observe regarding the effectiveness of Zero Suicide (https://zerosuicide.edc.org/evidence/outcome-stories).

Although each organization presented in the published Outcome Stories has approached Zero Suicide differently, there were several commonalities across their implementation activities. Nearly all health systems reported that their implementation began with key leadership individuals (e.g., clinical directors, vice presidents [VPs], directors of quality management) attending a Zero Suicide Academy training. Roughly half of the organizations administered a workforce survey to assess staff knowledge, practices, and confidence in providing suicide care. All facilities trained either clinical staff or all facility staff in suicide prevention techniques suitable to their positions. To identify at-risk patients, two-thirds of facilities reported using the Columbia Suicide Severity Rating Scale (C-SSRS), whereas one-third of facilities began their screening with the Patient Health Questionnaire (PHQ). Following identification, the most-common practice to engage patients in a dialogue around suicide prevention was the Stanley and Brown Safety Planning method, which helps patients identify and record warning signs, internal coping strategies, people and social settings that provide distraction, people they can contact for help, and ways to create a safe environment.^27^

Half of the facilities preparing safety plans also reported in their Outcome Stories that they counseled their patients on safe storage and access to lethal means. Many facilities also had established protocols for monitoring patient records and tracking death reports. These common elements align closely with the seven pillars of preventing suicide outlined in the Zero Suicide toolkit.

### 2.2.2 Implementation Challenges with Zero Suicide

Among the less publicized aspects of Zero Suicide are the challenges that health care systems have faced and how they have overcome these challenges. A few themes, however, have emerged within the literature regarding the challenges across each of the seven pillars of activities described in the Zero Suicide Toolkit. These challenges are described below.

#### Lead

One of the largest obstacles in implementation appears to be the cultural change needed across the system.^13^ Many providers are skeptical about their organization’s ability to prevent suicide and ultimately achieve zero suicide deaths.^28–30^ In an ongoing study of Zero Suicide in Massachusetts, researchers found that 44% of their clinician respondents disagreed that most or all suicide deaths are preventable.^31^ There is also concern about being liable for someone’s suicide death.^29^

However, experiences from health systems implementing Zero Suicide have shown that a culture shift that spans across the multiple settings and layers of an organization can happen with committed leadership.^32^

#### Train

Many providers, even after training, do not feel comfortable performing clinical tasks required to identify and care for someone at increased risk of suicide,^24,31,33^ such as safety planning with a patient. This challenge highlights the need for continued assessment of providers’ confidence and abilities in implementing suicide prevention activities. Such assessments can guide health systems’ continued efforts to offer tailored follow-up trainings. Additionally, research suggests that even brief trainings can have a positive impact on improving professionals’ skills and confidence to address suicide.^34^

Another challenge with training is staff turnover. Vermont has reported challenges with staff turnover among those who receive specialized training in suicide-focused care.^35^ This turnover results in ongoing investments in training and potential disruptions in offering high-quality evidence-based therapy to patients. Moreover, costs are incurred through training and loss of revenue when staff are taken offline to train, particularly in fee-for-service environments.

To minimize the burden of suicide prevention training on health systems, some researchers have proposed the implementation of Zero Suicide training in medical residency programs.^36^

#### Identify

Because there is not one universal screening tool currently recommended across health care settings, some multisite health systems struggle to standardize suicide-risk screening across sites.^37^ Screening tools vary in their approach for identifying suicide risk. For example, an individual may say they are having thoughts of killing themselves right now, which, with the Ask Suicide Screening Questions screening tool, would classify them as an acute positive screen;^38^ however, with the C-SSRS they might only be classified as moderate risk if they do not have a strong intent to act on those thoughts nor any specific plans. As a result, the threshold for placing a patient on a suicide-specific treatment pathway varies across sites. Some organizations also struggle with having a clear place to record the results of the screening tools within the medical record,^37^ which compromises the standardization and accurate recording of suicide-risk information.

Other researchers have emphasized the need to maintain and understand the patient’s narrative around suicidal risk and behaviors despite the use of structured screening instruments.^39^ Provider training can enable providers with the skills to listen to the patient’s narrative and to better understand the risk of suicide.

A developing focus within the identification element of Zero Suicide is how providers incorporate less-overt symptoms and risk factors when assessing an individual’s overall risk for suicide.^40^ Many screeners and assessments focus on the explicit communication of suicidal ideation. When assessing suicide risk, some of the more experienced providers may also consider less-overt risk factors, such as hopelessness and perceived burdensomeness, to determine their patients’ suicide risks.^40^ Incorporating these and other risk factors with suicide screeners and assessments will allow providers to more consistently and more comprehensively understand their patients’ suicide risks.

Another developing identification strategy is the use of machine-learning techniques with data available in the medical records to predict suicide risk and flag individuals in need of outreach.^41,42^ Although this approach has shown accurate classifications of individuals at general risk of suicide, some are concerned that these models result in high false-negative rates and that they poorly predict whether a person will die by suicide.^43^ Because of this concern, these prediction models should not be used as standalone identifiers of suicide risk; however, they can help guide and enhance a provider’s identification of those who may need to be engaged in suicide prevention efforts.^44^

#### Engage

A frequent challenge is retaining and engaging clients in treatment. In some of the clinical trials of cognitive behavioral therapy for suicide prevention (CBT-SP), researchers saw approximately a 25% dropout or noncompletion rate among clients.^45,46^ This dropout rate is very similar to those of cognitive behavioral therapy (CBT) in general.^47^ A major concern when treating patients at risk of suicide, however, is worsening suicide risk after dropping out of treatment. Providing follow-up calls and caring letters after missed appointments is one approach that providers have used to try and address the suicide risk among those who drop out from treatment.^48^ These follow-up and engagement protocols should be specified within a suicide care management plan (see the Zero Suicide Toolkit).

Increased availability of telehealth services during the COVID-19 pandemic may also help improve patient retention and satisfaction and reduce the number of missed appointments.^49,50,51^ These improvements may lead to increased provider productivity and better provider-patient relationships, thus helping sustain the work of Zero Suicide. However, more research is needed to quantify the impact of these recent changes in how well patients engage in treatment.

#### Treat

Many providers lack the skills to directly treat suicide risk among patients because they were never taught those skills in their formal education.^52^ Within the past couple of decades, suicide-specific treatments have been developed to help providers directly address suicide risk.^53,54^ As these interventions become more widely integrated with formal training programs, more providers will be enabled to address suicide risk within the health care setting.

Some providers inconsistently conduct comprehensive safety planning with their patients.^31,34^ Providers are also unlikely to counsel about firearm safety and lethal means restriction when they have not received training on how to do so.^55^ Even when safety planning or lethal means restriction discussions take place, they are not always accurately recorded in the electronic medical record.^37,56,57^ Because of these challenges, ongoing oversight and training are needed to help support providers and encourage high fidelity to the brief interventions for suicide prevention.

#### Transition

Studies have found that providing supportive contacts after psychiatric hospitalizations or emergency department visits can help reduce suicide; however, it is unclear what the most effective approaches are for offering this follow-up contact.^58^ Supportive contacts can be by phone call, text message, email, or postcard. The content of these contacts varies by study, ranging from a simple message that the provider cares and can be reached when needed^59^ to reassessing suicide risk and discussing coping skills.^60^ As a result, health care systems struggle to determine what should be defined as adequate and effective follow-up during transitions and how it should be monitored.^37^ Additional research on what is adequate follow-up to help in transitions of care will allow health systems to better implement more-effective follow-up contacts and ensure that they are done well.

#### Improve

Some articles have highlighted the need for and challenges with establishing consistent definitions of suicide risk and data collection processes when implementing Zero Suicide.^16,37^ Although these definitions can be challenging, they are an essential pillar for maintaining Zero Suicide efforts because they help identify what is going well and what needs to change. Not having an integrated medical and behavioral health EHR can pose additional challenges for sharing information and coordinating Zero Suicide efforts across settings and providers. To guide improvement, some health care systems use the Zero Suicide Organizational Self-Study to monitor how well they are implementing Zero Suicide.^19,33,61^

### 2.2.3 State Support for Implementing Zero Suicide

States enact a variety of efforts to help health care organizations overcome their challenges with implementing Zero Suicide. For example, Colorado is trying to raise additional state funds to help establish state-wide implementation of Zero Suicide.^62^ Utah conducts an annual Zero Suicide Summit and has established a state-wide learning collaborative for those implementing the program.^63^ Tennessee, via the Tennessee Suicide Prevention Network (TSPN), has also established a Zero Suicide Initiative Task Force to expand the implementation of Zero Suicide across other organizations within the state.^64^ Missouri Department of Mental Health trained all its contracted treatment providers through a Zero Suicide Academy and have helped 28 agencies adopt three or more components of the Zero Suicide Toolkit.^65^

## 2.3 Paying for and Sustaining Zero Suicide

Some implementations of Zero Suicide have been funded through grant programs. In 2016, the National Institute of Mental Health (NIMH) established a grant program called Products to Support Applied Research Toward Zero Suicide Healthcare Systems.^66^ Shortly thereafter, SAMHSA and the IHS established additional grant funding opportunities to support the implementation of Zero Suicide.^67,68,69,70^ Across all these funding mechanisms, more than 40 health care systems or grantees have been awarded funds. Although the federal grant opportunities have played an integral role in the initial implementation of Zero Suicide across the country, they are time limited and are not sustainable, long-term solutions to maintaining Zero Suicide activities.^71^

One potential for sustaining Zero Suicide is through health insurance reimbursement for specific suicide prevention activities. The Suicide Prevention Resource Center has recently established a guidance document outlining how to bill for screening, assessment, suicide-specific treatment, and follow-up care.^2,72,73^ There is no published evidence on the extent to which health care systems are using these billing codes to support Zero Suicide activities.

Several nonbillable tasks within Zero Suicide need to be supported financially by the health care system. These tasks may include staff training, data collection, data monitoring protocols, and use of staff members’ time to help lead the initiative and encourage a cultural change across the organization. One approach that organizations have taken to rationalize investment in these activities is to quantify the potential cost offset or return on investment that comes from reducing suicide attempts and rehospitalizations. Wellstone Regional Hospital in Indiana experienced an 82% reduction in 90-day readmission rates, and Riveredge Hospital in Illinois experienced a 21% decrease in 30-day readmission rates.^74,75^ The Chickasaw Nation Departments of Health and Family Services estimates that, because of the Zero Suicide program diverting patients from inpatient care, it saved more than $200,000 per year.^76^

There is also substantial evidence of the cost-effectiveness of specific suicide prevention activities and interventions that can be implemented as part of Zero Suicide:

▪ One study estimated that offering universal screening in the emergency department costs only $2,789 per additional attempt or death averted, and that offering universal screening plus additional support (i.e., safety planning, suicide hotline resources, and a series of follow-up phone calls over the course of the year based on the Coping Long Term with Active Suicide Program) costs only $5,020 per suicide attempt or death averted.^77^
▪ Another study examined suicide prevention activities that could be implemented in the emergency department and estimated that follow-up postcards both improved outcomes and reduced costs.^78^ The study also estimated that follow-up telephone outreach costs $4,300 per life-year saved, and CBT-SP (which is the most effective but also the most expensive) costs $18,800 per life-year saved.
▪ A study in Belgium estimated that a suicide helpline consisting of telephone or chat services resulted in net savings of more than €2,100 (or about $2,500) per person for the society.^79^
▪ The Attempted Suicide Short Intervention Program (ASSIP) was evaluated in a randomized clinical trial in Switzerland.^80^ The intervention consists of three manual-based therapy sessions followed by regular personalized letters over 24 months. Researchers found that the intervention had a 96% chance of being both less costly (due to reductions in hospitalizations and other health expenditures) and more effective in preventing reattempts.
▪ The implementation of a virtual Collaborative Assessment and Management of Suicidality protocol for suicidal patients in emergency departments was estimated to save $145 per patient from reduced personnel requirements and save hospitals an additional $412 per patient by reducing hospital readmissions by 50%.^51^
▪ One study conducted with suicidal U.S. Army soldiers examined the effects of brief cognitive behavioral therapy for suicide prevention (B-CBT) compared to treatment as usual.^81^ It found that B-CBT averted 23-25 more suicide attempts and 1-3 more suicide deaths per 100 patients than treatment as usual did. B-CBT was estimated to save the U.S. Department of Defense $15,000-$16,630 per patient.
▪ One systematic review of economic evaluations examined quality improvement initiatives that help prevent hospital readmissions, such as assessing patients risk and needs, engaging patients or caregivers, reconciling medication, connecting patients to clinicians, and supplementing care by usual clinicians.^82^ The review was not specific to suicide prevention interventions; however, some of the articles cited were focused on suicide prevention and the general quality improvement categories that were examined align with the main clinical pillars of the Zero Suicide initiative. The study found that, across all studies, readmissions declined by an average of 12.1%, and there were net health system savings of $972 per patient.

These studies suggest that, even without the support of grants and billing codes, implementing Zero Suicide may provide cost benefits to health systems and the society at large.

## 2.4 Gaps in the Literature and Purpose of Case Studies

Much practice-based evidence shows that Zero Suicide can have a substantial impact on reducing suicidal behaviors and outcomes. Documents and toolkits have been established to guide the overall implementation of Zero Suicide within health care systems. There has also been some discussion in the literature regarding challenges with implementation and guidelines for reimbursing clinical services related to Zero Suicide. The current literature, however, lacks detail on how health care systems are overcoming implementation and sustainability challenges with Zero Suicide. There is no information on approaches to funding the ongoing cost of Zero Suicide, particularly the nonbillable tasks. It is unclear which elements of Zero Suicide have the largest return on investment in suicide prevention.

To help fill these gaps in the literature, the next section of the report shares results from eight case studies of Zero Suicide. The cross-cutting themes highlight approaches to implementing and sustaining Zero Suicide and the challenges that have been encountered in the process.