# 1 Introduction

Suicide is a significant public health problem in the United States, and health care systems can play a critical role in preventing suicide. Among individuals who die by suicide, roughly half visited a health care setting in the 30 days preceding their death.^1,3–5^ About one-quarter of suicide deaths are among individuals who are actively receiving mental health treatment.^6^ Although many psychological, biological, social, environmental, cultural, and historical factors influence an individual’s suicide risk,^7^ some health care organizations have taken a proactive approach to identifying and addressing suicide risk among their patients.

The U.S. Air Force provides an early example of a health care system enacting a system-wide approach to preventing suicide.^8^ From 1990 to 2002, the Air Force implemented a multilayered intervention that included both community prevention efforts (e.g., social service provider involvement) and identification of individuals at risk for suicide in a health care system to facilitate their pathway to recovery and healing. The Air Force saw a 33% reduction in suicide deaths during this intervention.^8^

Another pioneering example in suicide prevention is the Perfect Depression Care program, which was developed within the HFHS following the 2001 Institute of Medicines Crossing the Quality Chasm report.^9^ The goal of this program was to eliminate suicide by improving patient partnerships, clinical care, treatment access, and information flow. Over the initial 4-year follow-up study, suicide rates among mental health patients were reduced by 75%, from approximately 89 per 100,000 to 22 per 100,000.^10^ As the HFHS has continued to invest in suicide prevention efforts, they have seen sustained reductions in the suicide rates among their mental health patient population.^11^

This early evidence of the impact that health care systems can have on reducing suicide rates led to establishing specific goals within the 2012 National Strategy on Suicide Prevention.^12^ Namely, Goal 8 promotes suicide prevention as a core component of health care services, and Goal 9 promotes and implements effective clinical and professional practices for assessing and treating those identified as at risk for suicidal behaviors. In the same year, the National Action Alliance for Suicide Prevention’s Clinical Care and Intervention Task Force reported on common factors that were key to the success that health care programs had in preventing suicide.^13,14^ The task force recommended that the comprehensive approach taken by health care systems be called Zero Suicide.

Since that recommendation was made, a comprehensive toolkit has been created to guide implementation (https://zerosuicide.sprc.org/toolkit), and Zero Suicide has been implemented in hundreds of facilities and health systems across the United States.^i^ The Surgeon General has also recently reiterated the need to adopt evidence-based care for suicide risk in health care organizations.^15^ Practice-based evidence has accumulated around the effectiveness of Zero Suicide in reducing emergency department visits, hospitalizations, and deaths. National studies are also being conducted to rigorously evaluate the impact of Zero Suicide initiatives that span multiple clinics and health systems.^16,17^ Recently, two peer-reviewed studies were published on positive outcomes associated with Zero Suicide. One study in Australia found that individuals who participated in the Zero Suicide clinical suicide prevention pathway experienced significantly lower risk of repeated suicide attempts within 90 days of the first attempt.^18^ In the United States, a study also found that increased fidelity to Zero Suicide practices resulted in a significantly decreased likelihood of suicide-related incidents.^19^

Currently, little is known about how organizations sustain the Zero Suicide initiative. SAMHSA has implemented three rounds of funding for Zero Suicide, but this funding only reaches a select number of health care organizations. It is unclear how organizations not receiving federal funding choose to implement and financially sustain their suicide prevention efforts. It is also unclear how organizations financially sustain their efforts after they have completed a grant related to suicide prevention.

This report was commissioned by the Office of the Assistant Secretary for Planning and Evaluation (ASPE) to better understand how organizations choose to implement and sustain a Zero Suicide initiative. In particular, the goal of this report is to address the following research questions (RQs):

1. How have organizations implemented Zero Suicide practices?
2. How have organizations sustained Zero Suicide practices?
3. Which components of Zero Suicide were most difficult to implement and sustain, and how were these difficulties overcome?

To answer these questions, we first reviewed the literature and consulted with subject-matter experts. Section 2 presents the results of this review. We then conducted in-depth discussions with providers and leaders at eight health care organizations that implemented Zero Suicide. Section 3 summarizes the findings from these discussions, and Appendix A has additional details about each of the case studies. Section 4 concludes the report by highlighting policy and practice implications for health care organizations and potential funders and supporters of Zero Suicide.

i To date, the Zero Suicide Institute estimates that more than 1,000 health care organizations are trying to implement Zero Suicide.