# Appendix E Examples of Forms and Letters Used with Zero Suicide

## Bridge Appointment Form Used by Riveredge Hospital

These appointments were conducted prior to discharge between the patient and a staff member who specialized in this task. The discharge and safety plans are reviewed, as well as ongoing medications and treatment needs. The staff member who fills out this form with the patient will provide a follow-up contact within the next few days after discharge (see below) and will forward necessary medical records to the medical provider with whom the patient will be meeting.

Riveredge Bridge Appointment Form

## Post Discharge Caring Call Form Used by Riveredge Hospital

This form includes specific questions that are asked during the follow-up calls after a hospitalization. It is an opportunity to hear how the patient is doing, determine whether the patient is receiving appropriate treatment, and assess for suicide risk and behaviors.

Riveredge Post Discharge Caring Calls Form

## Caring Letter Used by Centerstone

These letters are sent to patients when they have missed appointments and have not been responding to phone calls from Centerstone.

Centerstone Caring Letter Template