# Appendix D Process and Outcome Measures

Table D-1 Process and Outcome Measures by Zero Suicide Pillars of Implementation

Lead
- Results from workforce surveys
Train
- Staff trained in suicide prevention.; - Change in safety plan usage following trainings.
Identify
- Suicide-risk screenings completed.; - Suicide-risk assessment completed following positive screen.; - Patients identified at moderate or high risk of suicide based on the assessment.
Engage
- Completion of suicide care management plan following positive screen.; - Lethal means counseling following positive screen.; - Follow-up appointments that were attended by patients who screen positive.
Treat
- Rate of referrals to specialized treatment.; - Suicide prevention pathway declined or not completed by patient.
Transition
- Outpatient follow-up appointment scheduled within 48 hours of discharge.; - Patients who attended a follow-up appointment within 48 hours of discharge.; - Follow-up calls completed with a patient.
Improve
- Emergency department visits requiring psychiatric assessments; - Psychiatric inpatient admissions; - Rehospitalizations among patients; - Intentional self-harm among patients; - Suicide deaths among patients; - Policy changes related to suicide prevention efforts