# Appendix C Centerstone Enhanced Crisis Follow-Up Program Cost Study

The evaluation team developed a framework to capture projected and actual costs associated with providing the follow-up service to Centerstone clients. The purpose of this sub-study was to assess the general estimated cost-effectiveness of the program.

Cost Study Description: Centerstone Research Institute worked in partnership with Centerstone to assess the cost of the C-CFP model by collecting service data that corresponds to grant-funded service activities. Cost-related data for our program included the following: service completions, duration of service, and estimated costs of services. Figure C-1 illustrates how analyzing cost structure data complements program evaluation efforts to connect specific program inputs (and associated costs) with outcomes.

Figure C-1 Cost Study and Logic Model^89^

FIGURE C-1, Flow Chart Screen Shot: A Logic model integrating cost analysis with program evaluation. Context (such as priorities, mandates, mission/vision, local dynamics, stakeholder buy-in) influences the personnel and non-personnel resources, the activities, and the target participants which in turn influences the outcomes. There are also process evaluation aspects that include program inputs and program outputs which influence the overall outcome/impact evaluation. There is also the cost analysis which includes the direct and indirect costs and influences the overall cost evaluation.

Cost Study Data Collection Procedures:

▪ Because the Centerstone EHR captured the duration and service content of each call, separate cost-study databases were not generated to collect this data from staff. Thus, the Centerstone EHR functioned as the primary data collection tool for this cost study.
▪ The evaluation team met with the project director to itemize direct and indirect expenses associated with grant services. Direct expenses included staff time associated with making the follow-up calls to adults enrolled in the program. Indirect expenses included items such as the cost of hiring and training staff and recurring technology maintenance fees.
▪ The evaluation team also worked with the project director to pull EHR information related to the cost study such as the total number of calls completed during the grant, the range and average of time per call, the number of successful program completions and the recidivism rates (i.e., return to emergency department due to suicide risk) of program participants.

Cost Study Analysis: The C-CFP cost study analysis was completed according to best practice recommendations. Specifically, we used a guide created by James Bell Associates (i.e., Cost Analysis in Program Evaluation)^89^ to frame our primary analysis questions. Cost study outcomes are described below.

▪ Cost Study Question 2: What is the average cost per Centerstone Crisis High Risk Follow-up Program (CC-HRFP) participant enrolled?
  Centerstone was awarded $773,325 for the implementation of the C-CFP; of which a total of $650,045.56 was spent during the grant award period. With grant funds allocated, Centerstone enrolled and served 951 individuals in the C-CFP. Thus, the average cost per participant enrolled was $683.54.
▪ Cost Study Question 3: What is the average cost savings per individual diverted from a future episode of suicide-related psychiatric hospitalization?
  In preparation for this cost study, the evaluation team met with the Tennessee Department of Health in hopes of ascertaining data related to the average cost of suicide-related psychiatric hospitalization in the State of Tennessee. The evaluation team utilized data compiled by the Tennessee Department of Health for 2016 suicide and suicide attempt hospitalization rates.
  According to data compiled by Hongyan Ma, MS (Epidemiologist, Tennessee Department of Health), the average cost in Tennessee during the grant period per incidence of psychiatric hospitalization related to suicide (i.e., suicide attempt) was $26,975. Thus, after accounting for the cost of C-CFP program and nondiverted hospitalization costs, the average cost savings for a single individual diverted from a psychiatric hospitalization due to suicidal behavior is estimated to be $26,263.79 (i.e., 97.4% of cost saved).
▪ Cost Study Question 4: What is the estimated total cost savings of the CC-HRFP?
  In our study of the CC-HRFP, of the 951 enrolled, 914 (96.1%) were not hospitalized for a psychiatric reason related to suicide during their 30-day enrollment in the C-CFP, whereas only 37 (3.9%) were hospitalized for a psychiatric reason related to suicide. According to a study conducted by Madsen et al.^90^ comparing emergency department recidivism rates of patients hospitalized for suicidal (i.e., ideation, gestures, attempts) versus nonsuicidal psychiatric complaints, the 30-day recidivism rate was 17.5% for suicidal patients.
  Using the Madsen et al.^90^ study as a benchmark, we calculated the projected amount of emergency department and hospitalization-related cost savings for our participants. The Madsen et al.^90^ study outcomes are relevant as a theoretical benchmark considering that: (a) the sample was comprised of community-based adults; and (b) researchers analyzed recidivism rates for suicide-related risk (versus not a suicide risk) at 30 days. Specifically, we calculated the estimated total amount of cost saved using the process described below.
  Percent difference in recidivism rates: 17.5%^90^ – 3.9% (Centerstone C-CFP) = [underlined: 13.6%].
  Estimated number of individuals prevented from recidivism: 957 (C-CFP participants) * 0.136 = [underlined: 125] persons diverted from additional medical care within 30 days.
  Estimated cost savings of prevented psychiatric hospitalizations for suicide (i.e., if 125 persons had been hospitalized) = 125 persons * $26,975 (i.e., Tennessee 2016 average charge per suicide-related hospitalization) = [underlined: $3.371,875 − $650,045.56 (grant award spent for service provision) = $2,721,829.44].

Section VI: Conclusion

Initial descriptive indicators of the C-CFP program goals (e.g., number served, referral linkages, zero suicide deaths) suggest that the C-CFP was effective in meeting and exceeding its goals. Further, cost analysis estimates for the C-CFP suggested that the program yielded substantial systemic net savings. That is, the cost to implement the program was markedly less than the projected cost of providing subsequent medical care for projected future hospitalizations.