# Appendix B Zero Suicide Discussion Guide

This discussion guide is intended to facilitate key informant discussions with a range of Zero Suicide stakeholders during case study site visits. Specifically, information gathered will be used to inform answers to the following research questions:

RQ 1 How have programs implemented Zero Suicide prevention practices?
RQ 2 How have programs sustained Zero Suicide prevention practices?
RQ 3 Which components of Zero Suicide were most difficult (or impossible) to implement and sustain?

Note: Themes are in bold, and questions are colored and labeled according to the relevant research question (RQ). These questions may be further tailored to the study site and key informant. Discussions will center on Zero Suicide implementation and sustainability prior to COVID-19. However, when applicable, key informants will be asked to distinguish any changes made to the Zero Suicide initiative (e.g., implementation, financing) in response to the pandemic.

## 1 Background Information

1.1 What is your role at [site]?
1.2 Before talking about Zero Suicide, can you tell us about the general structure and types of services offered at your organization?
1.3 When did your site first begin to implement the Zero Suicide framework?

## 2 Implementation

2.1 What elements of Zero Suicide has your organization implemented? (RQ1)
  a. Which elements have you specifically helped implement? (RQ1)
2.2 How well have these elements fit with your organization’s other goals and stated health objectives? (RQ1)
2.3 How receptive have your clients been to the Zero Suicide initiative? (RQ1)
  a. How do you keep clients engaged in suicide prevention activities? (RQ1)
2.4 How has implementing Zero Suicide impacted the lives of your clients? (RQ1)
2.5 What changes in clinical practice took place, or are taking place, to implement Zero Suicide? (RQ1)
  a How has Zero Suicide impacted the flow of clients through your health system? (RQ1)
  b How has Zero Suicide changed the need for resources and capacity within your clinical practice? (RQ1)
  a What have been the hardest clinical practices to change? Why have they been hard to change? (RQ3)
  b What have been the easiest clinical practices to change? Why have they been easy to change? (RQ3)
2.6 What cultural changes took place, or are taking place, to implement Zero Suicide? (RQ1)
2.7 What infrastructure changes took place, or are taking place, to implement Zero Suicide? (RQ1)
  c How have these changes impacted the efficiency and effectiveness of delivering services and implementing Zero Suicide? (RQ1)
  d What changes were user friendly and well accepted? (RQ1)
  e What changes were not well accepted and later removed or revised? (RQ1)
2.8 What other organizations, if any, have you partnered with to implement Zero Suicide? (RQ1)
  f How have these organizations helped you implement Zero Suicide? (RQ1)
  g What roles have community partners played, if any? (RQ1)
  h What roles have state partners played, if any? (RQ1)
  i What partnerships would you recommend that other organizations try to establish while implementing Zero Suicide? (RQ1)
2.9 Overall, what have been the biggest barriers in implementing Zero Suicide? What have been the biggest facilitators? (RQ3)

## 3 Cost

Now we would like to talk a little bit about the cost of different aspects of the Zero Suicide initiative.

3.1 As your organization has implemented Zero Suicide, which elements, strategies, or activities had a low cost but a large impact? Which had a large cost but little impact? (RQ1)
  j What type of training is worth the cost? How much is it worth the cost? (RQ1)
3.2 Has your organization done any studies on costs or cost offsets/savings from Zero Suicide? If so, what were the results of those studies? (RQ2)
3.3 What are the billable services related to Zero Suicide? (RQ2)
3.4 What are the nonbillable services and activities related to Zero Suicide? (RQ2)
3.5 How would you rank the Zero Suicide services and activities by magnitude of cost? (RQ2)

## 4 Sustainability and Funding

4.1 What have been your organization’s primary strategies in sustaining Zero Suicide thus far? (RQ2)
4.2 What are your organization’s plans to sustain Zero Suicide in the future? (RQ2)
4.3 Did you receive any grant funding for Zero Suicide? (RQ1)
  a. What activities have the grants funded? (RQ2)
  b. How will you sustain those activities when grant funding ends? (RQ2)
4.4 What billing codes does your organization use to get reimbursed for clinical activities? (RQ2) (This question and the sub-questions below may be asked with question 3.3.)
  k How did your organization implement these billing codes? (RQ1)
  l What process does your organization have for recording the billing codes? What is your role in this process? (RQ1)
  m How frequently are billing codes used for Zero Suicide? Would it be possible to get aggregate estimates utilization for the different billing codes? (RQ1)
  c What are the biggest barriers to using billing codes? What are the biggest facilitators? (RQ3)
4.5 How have nonbillable activities been funded? (RQ2) (This question and the subquestions below may be asked with question 3.4.)
  a. Do you have a budget for Zero Suicide? (RQ2)
  b. If funded internally, what were the factors that led to the investment decision? How were funds shifted to pay for this? (RQ2)
  c. What other sources of funding has your organization leveraged to help pay for Zero Suicide? (RQ2)
4.6 What have been the biggest barriers in sustaining Zero Suicide? What are the biggest facilitators? (RQ3)

## 5 Closing

5.1 What have we not asked about that you think is important/relevant to understanding Zero Suicide within your organization? (RQ3)
5.2 If you were to do things again, what would you do differently? (RQ3)
5.3 What advice would you give to another program that wants to implement Zero Suicide? (RQ3)