# Appendix A Case Study Summaries

Below are brief summaries of the eight case studies that were conducted.

## Case Study Summary: Henry Ford Health System

Site Overview: Henry Ford Health System (HFHS) is a large, integrated health system that offers a range of services, from primary care to inpatient services, within urban areas of southeastern Michigan. It began to implement Zero Suicide practices in 2001, although the practices were called Perfect Depression Care at the time.

Staff Interviewed: Department Chair, Director of Health Policy and Health Services Research, Director of Adult Outpatient Psychotherapy, Division Lead of Pediatric Psychiatry, Psychiatrist leading Behavioral Health Integration, Primary Care Internist, Inpatient Psychiatrist

Timeframe of Discussions: July 17, 2020 - September 14, 2020

Implementation Themes:

Adoption/Early Implementation

▪ HFHS garnered support from senior leadership to improve depression care and reduce the number of suicide deaths and established a team of committed behavioral health providers across their organization (i.e., the Blues Busters).
▪ HFHS’s goal for suicide deaths is zero, and it wanted to achieve this aspirational goal through “perfect” depression care; it was not comfortable with saying that even one suicide death was acceptable.

Culture

▪ For more than a decade, HFHS has worked to change its culture around suicide prevention in the following ways:
  – Uniting around the aspirational goal of zero suicide deaths.
  – Addressing suicide independently and not just as a symptom of depression. HFHS was an early adopter of the knowledge that suicide occurs in many disorders and even among patients without a mental illness. This has helped strengthen their risk assessment.
  – Assessing for suicide risk and not just suicidal ideation. Nationally, suicidal ideation is the main symptom clinicians review in determining risk; however, for HFHS the absence of suicidal ideation does not mean no risk, and there are other symptoms and factors that may be more profoundly linked with suicide risk for a patient.
  – Helping providers be comfortable assessing for and addressing suicide risk.
  – Making suicide prevention a part of the organization’s identity from the moment people are hired until the day they leave (i.e., “this is what we do”).

Clinical Practice

▪ To support cultural and clinical changes, HFHS established clear guidelines and protocols. It trained staff on the protocols and had staff commit to following them.
▪ It also offered training to its clinical staff to be able to perform evidence-based psychotherapy to address suicide risk (e.g., CBT and DBT).
▪ Staff review charts to ensure protocols are being followed and perform critical incident reviews for any suicide attempts and deaths that occur among patients.
  – One person commented that these incident reviews have become more positive since implementing Zero Suicide because they feel more confident that they have done everything they could to prevent a suicide by following the Zero Suicide protocols.

Infrastructure

▪ HFHS has embedded Zero Suicide protocols into its EHR. Switching EHRs was a costly experience, but HFHS has incorporated the screenings, assessments, and record keeping necessary for documentation. The EHR also includes pop-ups and reminders to facilitate record keeping.
▪ They have developed an online PHQ-9 to send to clients before each visit to improve compliance with screening at every visit. HFHS is also working on making other outcome measures available online for the patient to fill out before their appointment.
▪ They identified low-cost, high-impact activities, such as including screening, caring contacts, and safety planning.

Sustainability Themes:

Funding Sources

▪ HFHS was awarded a grant from the National Institutes of Health in 2017 to evaluate the effectiveness of Zero Suicide and recently a grant from SAMHSA to implement a new emergency department model for Zero Suicide. However, most of HFHS’ Zero Suicide work is funded internally (e.g., operations funds to pay for training, website and educational materials).
▪ The department chair has had access to a philanthropy account to help pay for some training, and HFHS is also looking for an endowment through philanthropic channels to help establish an endowed chair in suicide prevention research.

One-Time and Ongoing Costs

▪ HFHS made some large, one-time investments to support evidence-based trainings among staff and pay for changes to its EHR. These were the largest expenses for implementing Zero Suicide.
▪ Providers can bill for some assessments and care coordination; however, most of the Zero Suicide work is not billable. The activities are embedded in standard practice.

Cost Savings

▪ An initial analysis by HFHS found cost savings to the organization.^20^ It is planning to do a more detailed cost study and anticipates savings due to the following:
  – Fewer emergency department visits and hospitalizations because challenges are recognized earlier in the outpatient setting and staff can address suicidal ideation in an outpatient setting.
  – Fewer unnecessary outpatient medical services; HFHS has already seen these services reduce within its Behavioral Health Integration program.
  – Higher provider productivity and lower rates of missed patient appointments.
▪ Some of the greatest financial benefits may be to health insurance plans and large integrated systems, rather than only outpatient behavioral health organizations.
▪ Financial sustainability was less of a concern than sustaining fidelity to the model.
▪ HFHS is willing to financially sustain Zero Suicide because they have embraced it.

Greatest Challenges:

Screening, Assessment, and Safety Planning

▪ Providers said that getting suicidal patients into a medical evaluation quickly and keeping crisis spots open when they are not always used can be challenging.
▪ Children and adolescents pose unique challenges in screening and assessment of suicide risk (e.g., impulsivity is weighted differently). Sometimes, they do not want their parents to know.
▪ Many patients are not willing to temporarily secure their guns outside of the home.

Recording and Sharing Information

▪ Sharing information about patients at risk for suicide across different health care systems is challenging (e.g., working with emergency departments outside of HFHS).
▪ There are competing priorities with investing in changes in their EHR.

Treatment Services

▪ Among patients at risk for suicide, not all care may be received at HFHS. For example, Medicaid patients must receive substance use disorder treatment in a community mental health center. Patients might have an emergency department visit not with HFHS.
▪ Due to medical students’ minimal exposure and graduate students’ mixed exposure to evidence-based psychotherapy, HFHS must ensure that staff are sufficiently trained in evidence-based psychotherapy.
▪ Trained staff experience turnover. As staff become more marketable with the additional skills, they may leave for another job.

## Case Study Summary: Centerstone

Site Overview: Centerstone is a nonprofit behavioral health system with centers operating in several states. Services include primarily outpatient care for mental health and substance use disorders. They also provide school-based behavioral health services. Centerstone has implemented Zero Suicide at Centerstone of Tennessee and Centerstone of Indiana, with planning and piloting beginning in 2012.

Staff Interviewed: Centerstone Research Institute CEO, VP of Health Integration, VP of Crisis and Disaster Management, Director of Suicide Prevention, Project Director of School-Based and Intensive In-Home Therapy Services, VP of Crisis Access and the VP of Quality Improvement, co-leads of the Zero Suicide Initiative in Indiana. In addition, the Executive Director of the TSPN, a partner of Centerstone, was also interviewed.

Timeframe of Discussions: July 24, 2020 - October 8, 2020

Implementation Themes:

Adoption/Early Implementation

▪ Centerstone (Tennessee) piloted a tailored approach of HFHS’s Perfect Depression Care model in 2013. Subsequently, Centerstone was able to visit Henry Ford to learn about Zero Suicide, which informed the development and implementation of Zero Suicide in Tennessee and Indiana.
▪ Centerstone (Tennessee) involved their Research Institute in adoption and implementation of Zero Suicide from the beginning; key staff, including the CEO, were part of steering committee efforts to identify best practices, monitor fidelity, and facilitate quality improvement.
▪ Implementation of Zero Suicide was a methodical process that prioritized staff buy-in, customization of the EHR framework, and fidelity to the model.
  – Both programs took 1 year to become fully operational. However, Indiana encountered a setback in their implementation when they switched EHRs in 2016, as the new vendor could not adopt the previously developed pathway, alerts, and data.

Organizational Culture

▪ Some Centerstone staff in both states were initially resistant to increased screening and schedule adjustments required within the Zero Suicide framework, so buy-in needed to be cultivated.
▪ Centerstone achieved this buy-in and associated implementation by:
  – Establishing that suicide prevention is part of every individual’s job “from day one.”
  – Embedding the screening/assessment process through the workflow of the EHR.
  – Conducting repeated trainings and workforce surveys to show that Zero Suicide is a long-term priority.
  – Using monthly fidelity audits of screening/enrollment to provide feedback to clinician and supervisor.

Clinical Practice

▪ Suicide-risk screening has been integrated at the beginning of every visit to identify individuals at high risk of suicide.
▪ The EHR tool that all clinicians use includes the PHQ-9 and the C-SSRS algorithm with automatic scoring and, as appropriate, prompts to enroll the individual in the suicide prevention pathway. Overriding the pathway recommendation requires a clinical explanation.
▪ Those who are placed on the pathway are denoted in the EHR system and receive suicide prevention services (e.g., Stanley-Brown safety plan, caring contacts, suicide-specific therapy).
▪ Screening and intervention vary slightly in the school-based setting in that it incorporates more hands-on activities (e.g., drawing) into the C-SSRS to allow the child to express their feelings and involves the school and parents/guardians in safety planning.
▪ Centerstone (Tennessee) has a director of suicide prevention to oversee all aspects of suicide prevention work, whereas Centerstone (Indiana) does not have a dedicated director of suicide prevention; instead, this is an additional responsibility of a leader.

Infrastructure

▪ Centerstone (Tennessee) has embedded Zero Suicide into its EHRs through custom modifications made by the information technology department and overseen by quality improvement and data analytics staff.
  – In addition to automatic scoring and enrollment in the suicide prevention pathway, the EHR tool provides alerts to providers when patients enter and exit the pathway and when a pathway patient “no shows” for an appointment and facilitates tracking fidelity (e.g., rates of enrollment for clinical staff) and key outcomes (e.g., length of time on pathway, treatment adherence).
  – Monthly audits are conducted by the quality improvement team on the enrollment process and pathway.
  – Post-incident review process informs screening and prevention protocols.
▪ Centerstone (Indiana) is still refining its EHR infrastructure with the new vendor after changing its EHR system in 2016. It has implemented an enrollment report that identifies who is on the suicide prevention pathway. It can also track completed C-SSRS and whether a provider opts not to place a patient in the suicide prevention pathway.

Sustainability Themes:

Funding Sources

▪ Early implementation at Centerstone was an internally funded agency initiative.
▪ When possible, it has used grants to support training costs (e.g., CBT-SP and DBT training).
▪ Centerstone was recently awarded two SAMHSA grants directly related to Zero Suicide: the COVID-19 Emergency Response for Suicide Prevention and Implementing Zero Suicide in Health Systems.
▪ The data analysis work led by the Research Institute has been successfully written into grants.

One-Time and Ongoing Costs

▪ Training is costly, as it incurs lost staff time and revenue. However, training staff on suicide prevention is considered a necessary investment.
▪ The Research Institute has used some grants and invested funds internally to create a new simulation-based training program.
  – It plans to make this program publicly available at one-third the cost of traditional training.
▪ An ongoing cost in Centerstone (Tennessee) is the Director of Suicide Prevention position.
▪ Most Zero Suicide activities are embedded in standard practice and are not billed as separate services.

Cost Savings

▪ The Centerstone Research Institute studied the cost impacts of its Enhanced Crisis Follow-Up Program that was originally funded under a grant and estimated $2.7 million in savings due to prevented psychiatric hospitalizations for suicide. The Institute plans to use this information to advocate for billing changes to support enhanced crisis follow-up services.
▪ The Research Institute is also trying to demonstrate that better training is cost-effective--with the goal of getting the cost of training bundled in future contracts.
▪ Screening and workforce surveys were identified as low-cost, high-impact activities, whereas EHR customization was described as a high-cost, high-impact activity. Safety Planning was also seen as low-cost and high-impact, but there was concern about fidelity to the model that would limit impact.

Greatest Challenges:

▪ There is not a dedicated dashboard to see process measures across patients, nor is there an easy way for quality improvement staff to see one clinician across all domains (e.g., screening, enrollment).
▪ Most people who die by suicide at Centerstone are not enrolled in the pathway; this may be because patients do not have suicidal ideation at screening or are unwilling to disclose suicidal ideation or intent.
▪ Many staff come into Centerstone without sufficient suicide prevention training. Pulling a clinician offline for needed training loses revenue by not providing face-to-face care during that time.
▪ The EHR systems do not track suicide attempts.
▪ Indiana’s EHR system does not have the same level of adaptability and data processing as Tennessee’s.

## Case Study Summary: AtlantiCare

Site Overview: AtlantiCare is an integrated health system that includes two inpatient hospitals and over 100 outpatient clinics in southeastern New Jersey. It is the designated screening center for commitment to mental health treatment in Atlantic County. AtlantiCare first implemented Zero Suicide in 2015.

Staff Interviewed: AtlantiCare President and CEO, Senior VP and Chief Medical Officer, Chief Medical Ambulatory Officer, System Executive Director for Behavioral Health, Director of Quality Management, Clinical Director for Acute Psychiatry, Associate Chair of the Department of Psychiatry, SPC, Oncology Social Worker

Timeframe of Discussions: September 16, 2020 - October 1, 2020

Implementation Themes:

Adoption/Early Implementation

▪ In response to an increase in suicides and suicide attempts within the organization’s service population, AtlantiCare developed an interdepartmental suicide prevention steering committee in 2014. The team explored best practices and found that Zero Suicide aligned well with their organization’s philosophy around suicide prevention.
▪ Select members of the steering committee attended Zero Suicide Academy in 2015 and garnered support from senior leadership at AtlantiCare to host an on-site Academy and implement Zero Suicide across the organization.
▪ AtlantiCare conducted a workforce survey and found that many providers were initially uncomfortable asking about suicide. The on-site Zero Suicide Academy helped establish buy-in among medical and administrative leads across the organization. Consistent training over time has helped providers become more comfortable asking about and addressing suicide risk.

Culture

▪ Adapting organizational culture to embrace Zero Suicide included the following:
  – Establishing suicide as a problem in the community, not limited to behavioral health patients.
  – Establishing suicide prevention as a system-wide initiative (i.e., it is everyone’s responsibility).
  – Framing the goal of zero suicides as aspirational.
  – Educating providers about suicide, showing greater empathy, and knowing how to screen for and address suicide within their health care system.
  – Prioritizing the treatment of suicidality when it is identified in a patient at any health care setting.

Clinical Practice

▪ To support clinical implementation of Zero Suicide, AtlantiCare created a position for a full-time SPC to maintain contact with patients on a suicide care management plan. The SPC communicates with patient providers to exchange relevant information on patient risk screenings.
▪ Suicide-risk screening was integrated as routine care in service lines across primary care, emergency, and inpatient settings. They use the C-SSRS screening tool, followed by a full assessment as needed. At least one department advocated to also use the PHQ with their patients.
▪ At the start, they provided hundreds of staff with CBT training. They have since implemented a train-the-trainer model to educate AtlantiCare providers on suicide prevention.
▪ There is an emphasis on making sure people are operating at their highest skill level so that work is distributed effectively across positions. For example, they have psychiatrists focus on providing services, and others coordinate schedules and facilitate care.

Infrastructure

▪ AtlantiCare has multiple, nonintegrated EHRs across different departments.
  – One EHR system spans across 60%-70% of practices, including inpatient services and emergency department.
  – AtlantiCare has a dedicated information technology team that helps manage the different EHRs, including integrating screenings and assessment and tracking electronic data points.
▪ AtlantiCare established a Zero Suicide e-dashboard that pulls information from the various EHRs.
  – It tracks fidelity to the model and captures how many patients are served through Zero Suicide.
  – It aligns with the standards established by the Joint Commission.
▪ Zero Suicide has become “hardwired” into AtlantiCare’s system through having screening and reporting mechanisms programmed in their EHRs, regularly requiring trainings to expand and reinforce suicide prevention skills, and spreading the approach across the entire organization.
▪ As a result of their efforts, AtlantiCare has seen some reductions in rehospitalizations, and they achieved a year and a half with no suicide events identified in their monitoring system.

Sustainability Themes:

Funding Sources

▪ AtlantiCare funded early implementation of Zero Suicide internally, which involved both a financial commitment from the health system as well as a significant time commitment among behavioral health leaders, IT, and other service lines across the system.
▪ The AtlantiCare Foundation is a locally based philanthropic organization associated with AtlantiCare which has also helped to fund Zero Suicide.
▪ AtlantiCare was recently awarded a SAMHSA COVID-19 Emergency Response for Suicide Prevention Grant, which will support training/boosters and fund an additional full-time SPC position.
  – The grant consists of a component for domestic violence, which allows AtlantiCare to educate the staff of domestic violence organizations on how to reduce the number of suicide deaths and suicide attempts among victims of domestic violence.

One-Time and Ongoing Costs

▪ AtlantiCare made large, one-time investments to support remote and on-site Zero Suicide Academy and CBT trainings among staff system-wide.
▪ Ongoing costs include the SPC position and information technology. The SPC position currently operates at capacity, so the need to keep up with increasing caseloads is recognized.
▪ Most Zero Suicide activities are embedded in standard practice and are nonbillable. There are no specific billing codes for suicide prevention, and although case management may be billed, AtlantiCare is not reimbursed much money.

Cost Savings

▪ Screening was described as the main low-cost, high-impact activity, as it is believed to have saved lives by identifying at-risk individuals and providing them with needed care. Training was considered a high-cost, high-impact activity that improves quality of therapy delivered across patient populations.
▪ AtlantiCare has not completed any formal cost offset studies, but they will be able to assess cost savings in the future using a recently implemented e-dashboard.
▪ The organization recognizes the value of behavioral health and operates under the assumption that it reduces rates of other medical services.
  – Although behavioral health generally runs at a loss, AtlantiCare only perceives it as motivation to improve efficiency in their services.
▪ AtlantiCare is willing to financially sustain Zero Suicide because the cost of lives cannot be quantified.

Greatest Challenges:

▪ AtlantiCare expressed that there are still some silos in how patients are cared for and in where patient information is recorded, although in the past 3-5 years, there has been increased awareness around mental health and its significance. A project manager position in early implementation would have helped facilitate everyone’s efforts around Zero Suicide.
▪ Multiple EHRs required additional work on the part of information technology, both in terms of initial customization for screening/assessment and ongoing management.
▪ Getting buy-in and developing confidence among medical providers with limited experience in suicide prevention was difficult. The referral process can also be time-consuming for providers.
▪ Since many of the patients AtlantiCare provides for are Spanish-speaking and bilingual, having on-site bilingual therapists across all health departments, primarily Oncology, would help increase reach.

## Case Study Summary: Mental Health Center of Greater Manchester

Site Overview: The Mental Health Center of Greater Manchester (MHCGM) is a private, nonprofit system and community mental health center. It provides mental health services across several levels of care (e.g., residential, intensive outpatient, and outpatient) among both adults and adolescents. MHCGM started implementing Zero Suicide in 2017.

Staff Interviewed: Executive VP and Chief Operating Officer, Director of Quality Improvement, Director of Revenue Cycle Management, Director of Electronic Medical Records, Mobile Crisis Team Coordinator, Transition Team Leader, Peer-Support Specialist

Timeframe of Discussions: October 13, 2020 - October 30, 2020

Implementation Themes:

Adoption/Early Implementation

▪ In early 2017, family members of a patient who died by suicide met with the CEO to discuss ways to prevent suicide from happening among other patients. This conversation led MHCGM leadership to put a renewed effort and focus on suicide prevention.
▪ Select staff attended a Zero Suicide Academy that took place with several local organizations.
▪ MHCGM then established a Zero Suicide Implementation Team, which continues to meet monthly.
▪ One of the first activities of this Implementation Team was to conduct a staff survey regarding knowledge and comfort managing suicide risk. The survey results guided the development and delivery of specific trainings to improve staff’s confidence and abilities in addressing suicide risk.
▪ MHCGM developed a Zero Suicide Foundations training and partnered with the New Hampshire chapter of NAMI to offer Connect training to all nonclinical staff members.

Organizational Culture

▪ Zero Suicide has become a top priority for MHCGM and has become integrated into its culture through regular trainings among all clinical and nonclinical staff.
▪ Everyone in the organization is involved in suicide prevention; even staff involved in billing are trained to recognize concerns related to suicide and get an individual connected with a therapist.
▪ Over the past few years, New Hampshire has also implemented a delivery system transformation 1115 Medicaid waiver, which has supported a culture of suicide prevention across the state through standardized screening and trainings.

Clinical Practice

▪ MHCGM screens for suicidal risk during each visit using the risk screenings and assessments embedded in service notes, PHQ, and/or the C-SSRS. Those who screen positive for suicide risk also develop a safety plan with their mental health provider.
▪ MHCGM works with local emergency departments to perform caring contacts after discharge.
▪ MHCGM also has care transition teams that help individuals after psychiatric and medical hospitalizations, emergency department visits, and incarcerations to get access to follow-up treatment and other needed community resources.
▪ Over the past 4 years, MHCGM has established a mobile crisis response team that conducts check-ins and responds to suicide-related 911 calls and requests from first responders for postvention. This team works closely with the local police department to provide 24/7 emergency response for mental and emotional crises.
▪ Certified peer-support specialists have been integrated with the care transition team, mobile crisis response team, and other services offered at MHCGM.
▪ For suicidal patients, MHCGM has trained clinical staff to provide CBT-SP, DBT for both adults and adolescents, Teachable Moment Brief Intervention (TMBI) for suicide attempt survivors, safety planning, and counseling on access to lethal means.

Infrastructure

▪ MHCGM has embedded Zero Suicide into its EHR through custom modifications:
  – Embedded PHQ, C-SSRS, Hope scale, and other screening assessment questions.
  – Electronic safety plan form.
  – Caring contact letter templates.
▪ MHCGM is working with the EHR vendor to include a color-coded Risk Console that will denote patients on the suicide prevention pathway who are at high risk for suicide.

Sustainability Themes:

Funding Sources

▪ MHCGM received a small local grant (~$25,000) to help support its monthly Zero Suicide Implementation Team meetings and some internal training to new staff.
▪ Trainings were also paid for, in part, through the Medicaid 1115 waiver and through internal investments by MHCGM.
▪ The care transition team was initially funded by the Medicaid 1115 waiver. The following changes have been made to make this service more sustainable:
  – The state Bureau of Mental Health Services health department now allows for presumptive eligibility for functional support services during care transitions, which helps cover some of the initial assessment and support.
  – The teams bill for targeted case management.
  – MHCGM is developing a partial position funding through grants to be able to provide transition team services to those whose insurance carriers do not pay for these critical, life-saving interventions.
▪ The state contracts with MHCGM to help pay, in part, for the mobile crisis team.
▪ MHCGM has established contracts with local emergency departments to provide assessment and crisis response services.
▪ Leadership is looking for ways to help pay for some of the Zero Suicide activities through grants regarding tangential but overlapping topics, like homelessness and COVID-19.

One-Time and Ongoing Costs

▪ Training is an ongoing and expensive cost, but MHCGM has tried to minimize this in several ways:
  – Using or creating online trainings that can be done at flexible times without the continuing cost of someone delivering the training.
  – Establishing a train-the-trainer approach with CBT-SP and TMBI.
  – Becoming experts in the field of DBT so that they can receive reimbursement for external trainings.
▪ EHR changes have also been an expensive one-time cost.

Potential Cost Savings

▪ The mobile crisis team has been able to divert 94% of its clients away from hospital emergency departments into appropriate behavioral health services.
▪ The care transition program has also reduced emergency department visits by 70% and hospital bed days by 90%.

Greatest Challenges:

▪ The EHR vendor has been slow to make the changes requested by MHCGM.
▪ MHCGM is still trying to expand its reach into the community to help prevent suicide. Since the beginning of the pandemic to the time of the discussions in September 2020, MHCGM had none of its patients die by suicide; however, there were approximately 30 suicide deaths in the community.
▪ There is a lack of inpatient mental health resources in the community, which mean that some patients wait in the emergency department for weeks. Zero Suicide has helped reduce this challenge by enabling MHCGM staff to address suicide in noninpatient settings.

## Case Study Summary: Kaiser Permanente

Site Overview: Kaiser Permanente is a large integrated health system divided into eight regions across the United States. System-wide suicide prevention efforts started in 2014 and then focused on the Zero Suicide approach starting in 2016. This case study includes perspectives from the national implementation team and Kaiser Permanente Care Management Institute (CMI) but focuses primarily on the experiences with Zero Suicide in the Kaiser Permanente Northwest (KPNW) region.

Staff Interviewed: Senior Consultant of Mental Health and Wellness (CMI), Principal Consultant of Evaluation and Analytics (CMI), Psychiatrist and National Zero Suicide Clinical Lead (KPNW), Program Manager (KPNW), Director of Addiction Medicine (KPNW), Director of Quality for Mental Health and Addiction Medicine (KPNW), Mental Health Service Area Manager (KPNW), Rapid Access Therapist (KPNW), Primary Care Behavioral Health Consultant (KPNW)

Timeframe of Discussions: October 19, 2020 - October 30, 2020

Implementation Themes:

Adoption/Early Implementation

▪ In 2016, CMI established the Mental Health and Addiction Leaders of Operations (MHALO) group, which decided to make suicide prevention a key priority area across all Kaiser Permanente regions.
▪ MHALO decided to focus suicide prevention efforts on the core activities of screening (using the PHQ and the C-SSRS for those who have had recent thoughts of suicide), safety planning, and follow-ups.
▪ Leaders in each region were then selected by MHALO to help implement suicide prevention activities. These leaders meet every other month as a suicide prevention learning collaborative.
▪ KPNW also established a Zero Suicide Committee. This committee adopted a system-wide approach after analysis of mortality data showed that only targeting behavioral health patients would miss approximately 60% of suicide deaths among KPNW members.
▪ Zero Suicide in KPNW was implemented broadly across thousands of primary care providers, mental health providers, and addiction medicine providers.
▪ There was an initial KPNW 2-day kickoff training in 2018 to establish the aspirational goal of zero suicide deaths and to teach providers about using the PHQ-9, C-SSRS, and safety planning.

Culture

▪ Zero Suicide fit within the organization’s broader initiatives of feedback informed care, patient safety, and risk management.
▪ There was some initial concern regarding the name Zero Suicide, but Kaiser Permanente started to frame it as “zero defects in care for suicidal patients” and an aspirational goal of zero suicide deaths.
▪ The culture among mental health providers changed faster than among primary care providers.

Clinical Practice

▪ In KPNW, mental health and addiction medicine use a program called Tridiuum, which prompts patients to fill out the PHQ-9, C-SSRS, and other risk screeners prior to a scheduled appointment.
▪ Primary care providers wait until the patient is present or in a virtual waiting room before delivering the PHQ-9 and C-SSRS.
▪ KPNW has been expanding its Primary Care Behavioral Health Consultants program to help address suicide risk when someone screens positive on the PHQ-9 and C-SSRS.
▪ To help with access to mental health services, KPNW also has a crisis call center that will triage an individual’s presenting mental health needs and counsel on access to lethal means; a solutions team that provides phone-based services to help connect a patient to services; and a rapid access team to provide bridge appointments for established mental health patients.
▪ Safety planning is provided by all behavioral health providers; however, when providers do not have sufficient time and the patient is lower risk, they will establish a truncated version that focuses on suicidal thoughts and behaviors, ways to keep the environment safe, and safety contacts.
▪ KPNW has recently hired peer specialists to provide caring contact following behavioral health-related emergency department visits.
▪ If KPNW is unable to provide a follow-up mental health appointment within 48 hours of an emergency department visit or hospitalization, they have contracted external mental health providers to provide that service.

Infrastructure

▪ Nationally, CMI has established eight suicide prevention metrics (see https://zerosuicide.edc.org/evidence/outcome-story/kaiser-permanente). They have established data use agreements with the state’s vital statistics department to inform their metrics on suicide deaths.
▪ CMI has also helped establish resources in the EHR for recording C-SSRS and safety plans.
▪ KPNW conducts quarterly chart reviews to check for compliance with Zero Suicide practices.
▪ KPNW also provides booster training sessions to units upon request or when there is low compliance.

Sustainability Themes:

Funding Sources

▪ The MHALO group received a 3-year internal Kaiser Permanente grant to sponsor zero suicide implementation across the regions. This grant funded someone at the national level to help coordinate efforts, and it helped pay for some trainings around safety planning and a Zero Suicide Academy across regions.
▪ KPNW also received a small internal grant to help with EHR changes.
▪ Most Kaiser Permanente regions can operate on their existing budget integrating Zero Suicide into their current workflow.
▪ All KPNW therapists also have a training budget (40 hours of emergency department leave per year) that helps cover some of the training expenses related to Zero Suicide.
▪ Five Kaiser Permanente regions are participating in a grant from NIMH to evaluate Zero Suicide impacts.

One-Time and Ongoing Costs

▪ The major costs of implementing Zero Suicide are training and staff time.
▪ In many situations, salaried individuals take on additional tasks related to suicide prevention, though this does not change compensation.
▪ Booster training sessions are typically done during pre-established department meetings or huddles.
▪ KPNW stopped conducting monthly meetings with the Zero Suicide Committee as they transitioned from an implementation phase to a maintenance and sustainability phase.
▪ Expanding the number of Behavioral Health consultants has been expensive, but it is a part of a larger initiative to improve behavioral health integration and access to mental health treatment.

Cost Savings

▪ Initial discussions in KPNW presented this work as potentially cost neutral.
▪ There are increased expenses with identifying more individuals in need of treatment.
▪ There are potential savings from preventing repeat suicide attempts resulting in hospitalizations, lost productivity from providers who have a patient die by suicide, and liability or negative publicity from a suicide death that becomes very public (which KPNW experienced just before implementing Zero Suicide).

Other Drivers of Sustainability

▪ Washington State requires providers to be trained in suicide prevention.
▪ Oregon has a bill requiring caring contacts be sent following behavioral health–related emergency department visits.

Greatest Challenges:

▪ Maintaining fidelity to safety planning has been difficult. Regions track whether safety planning is done, but not the quality of safety planning. CMI plans to study this in the coming year.
▪ KPNW recently focused on reducing administrative time, which sometimes conflicts with the need to offer additional training and support to maintain fidelity to safety planning.
▪ There is a delay in access to comprehensive data on suicide death outcomes.
▪ Kaiser Permanente is still working to improve the EHR so that providers can more readily know if a patient was recently in the emergency department for suicide risk, or if a patient who cancelled an appointment was recently at risk of suicide.

## Case Study Summary: Chickasaw Nation

Site Overview: Chickasaw Nation is a federally recognized, Native American tribe comprising 13 counties in south-central Oklahoma. Chickasaw Nation provides all tribal citizens with health care, including integrated behavioral health services at the Chickasaw Nation Medical Center and outpatient clinics. Chickasaw Nation Department of Family Services, in collaboration with the Chickasaw Nation Department of Health, began implementing Zero Suicide in 2015, mentored by the Oklahoma Department of Mental Health and Substance Abuse Services (ODMHSAS).

Staff Interviewed: Executive Officer of Integrated Services Division, Director of Medical Family Therapy, Senior Manager of Medical Family Therapy, Clinical Informaticist, Billing Office Director, Coding Supervisor, Executive Revenue Officer, Emergency Department Chief, Programs Director of Heartline

Timeframe of Discussions: November 6, 2020 - December 3, 2020

Implementation Themes:

Adoption/Early Implementation

▪ ODMHSAS received a SAMHSA grant to implement Zero Suicide in Oklahoma hospital systems in 2015. Chickasaw Nation was selected to receive guidance--not funding--to start Zero Suicide in its emergency department in 2016. The mentorship took place over 3 years, spanning a system-wide transformation and use of universal screening.
▪ Prior to Zero Suicide, there was no risk stratification (i.e., low/medium/high risk) in place, so any suicidal patients were automatically transferred to inpatient settings via emergency order of detention.
▪ Chickasaw Nation prioritized a standardized approach to screening across settings, including primary care. This universal screening, coupled with development of a suicide care pathway (termed the high-risk registry), was intended to prevent emergency department admissions.
▪ Implementation of Zero Suicide at Chickasaw Nation has been facilitated by key staff buy-in and a state-funded partnership with HeartLine, a 24-hour on-call behavioral health service that has been contracted as a gap filler to provide emergent crisis assessments on nights, weekends, and holidays.

Organizational Culture

▪ Chickasaw Nation has achieved and maintained buy-in throughout the health system through repeated emphasis of the importance of Zero Suicide in staff meetings and with heads of departments, citing the Joint Commission’s support of Zero Suicide as an evidence-based practice.
▪ Nursing leadership and buy-in around policy and protocol changes were considered especially important when first integrating standard screening across the entire system, as nurses are most active with at-risk patients.
▪ Providers who were previously used to relying on emergency order of detention in cases of suicide risk began to trust the standardized process, in part because therapists are readily available to help in cases of a positive screen; behavioral health providers were embedded in all clinics following Chickasaw Nation’s transition to integrated care in 2014.
▪ Accountability checks and chart reviews are conducted monthly to ensure that the process has been followed correctly; any necessary adjustments are made through targeted training with staff.

Clinical Practice

▪ Screening has been integrated at the beginning of every visit to assess level of risk for suicide. Screening protocols are standardized across primary and emergency care settings.
▪ Clinicians use the PHQ-2, PHQ-9, and the C-SSRS.
  – All patients are screened using the PHQ-2 and PHQ-9 and, if necessary, the C-SSRS. If a patient is above the cutoff, a medical family therapist is assigned to create a safety plan and HeartLine referral for follow-up contacts, with additional outreach occurring within 72 hours.
  – The C-SSRS is then used to further stratify levels of moderate and high risk among those who screened positive. The determination of in-person follow-up versus inpatient referral is made based on patient’s level of risk and support system.
▪ There is an on-call behavioral health service at the emergency department on nights and weekends to complete crisis assessments, with nurses submitting an “automatic consult” to notify appropriate staff in the Medical Family Therapy program when a patient has screened at risk for suicide.

Infrastructure

▪ The EHR was originally developed in 1989 for the U.S. Department of Veterans Affairs, and later passed to IHS who made it available to tribes.
  – The EHR’s involvement in Zero Suicide is primarily limited to recording PHQ scores and creating the automatic consult described above. Once patients are identified for the suicide prevention pathway, the resulting high-risk registry is managed externally to the EHR.
▪ The high-risk registry tracks all Zero Suicide reporting elements, including each patient’s suicide risk (color-coded based on C-SSRS scoring guidelines), recent service utilization, safety plan, and HeartLine activity. The registry additionally facilitates scheduling for repeated assessments.

Sustainability Themes:

Funding Sources

▪ Chickasaw Nation received initial training around Zero Suicide (including select staff attending a Zero Suicide Academy) through the state’s SAMHSA grant, valued at approximately $125,000.
▪ Early implementation of Zero Suicide activities was largely an internally funded initiative, with staff incorporating it into their existing roles.
▪ When possible, Chickasaw Nation has used state funds and existing grants to support Zero Suicide.
  – Oklahoma funds HeartLine’s role in implementing Zero Suicide, which is valued at approximately $30,000/year. The state additionally provided funds of $25,000 for a portion of a clinic informaticist’s salary for 1 year to support data collection efforts around Zero Suicide.
  – An IHS grant covers all suicide training and purchase of mouse pads with crisis protocols.
▪ Chickasaw Nation was recently awarded a SAMHSA grant for the COVID-19 Emergency Response for Suicide Prevention, which will support additional internal and external Zero Suicide Academies.

Costs and Cost Savings

▪ The Joint Commission standards require patient sitters for moderate- to high-risk patients in inpatient settings, which has required contracting a valet service at the hospital.
▪ Chickasaw Nation provides care at no cost to their patients. Although it receives federal funding via IHS, it relies heavily on third-party revenues. As a result, billing is a strategic process that works to capture third-party revenue when possible.
  – Billing codes are used for screenings and crisis care for the ~60% of patients on insurance.
  – Care for uninsured patients is uncompensated, so Chickasaw Nation is encouraged to enroll high-volume and high-usage patients into a premium assistance program.
  – Chickasaw Nation has a self-funded insurance plan for all employees, resulting in further emphasis on preventive care to circumvent costly inpatient admissions.
▪ The coding team who prepares claims has added two behavioral health coders in response to higher volume of screenings and crisis care.
▪ An internal study assessing cost offset of screenings on inpatient admissions demonstrated cost savings even without accounting for the inpatient costs incurred via patient sitters and tribal police.

Greatest Challenges:

▪ The EHR was cited as the largest barrier to Zero Suicide, due in large part to the lack of customization and patient-tracking mechanisms and to difficulty in extracting relevant data.
  – The EHR’s suicide screening process is dictated by user entry, which can be a potential constraint in cases of nonresponse or mistakes.
▪ Joint Commission standards and recommendations around suicide prevention dictate hospital policies (e.g., presence of patient sitters) that may not be necessary or beneficial in all cases.
▪ Zero Suicide is implemented across multiple settings (e.g., outpatient facilities, emergency department), with staff composition differing across shifts. Communication with afterhours contractors can be difficult, so additional emphasis is placed on ongoing conversations throughout the week to resolve any issues.

## Case Study Summary: Riveredge Hospital and Universal Health Services

Site Overview: Universal Health Services (UHS) is the largest system of inpatient psychiatric hospitals in the United States. Riveredge Hospital is owned by UHS and is the largest freestanding psychiatric hospital in Illinois. It serves the Greater Chicago area, offering over 200 inpatient beds and partial hospitalization, intensive outpatient, and outpatient services. Several facilities within UHS have implemented Zero Suicide; however, Riveredge was an early adopter, starting their efforts in 2016.

Staff Interviewed: CEO, former Chief Clinical Officer (CCO), Director of Performance Improvement, Director of Business Development, Director of Therapeutic Services, Coordinator of Outpatient Assessment and Referral, former Coordinator of Assessment and Referral, UHS Senior VP of Clinical Services

Timeframe of Discussions: November 10, 2020 - December 2, 2020

Implementation Themes:

Adoption/Early Implementation

▪ UHS has conducted several virtual Zero Suicide Academies to introduce the concept of Zero Suicide to cohorts of hospitals and to train senior staff at the hospitals regarding the seven elements of Zero Suicide.
  – Rather than doing a concentrated 2-day event, UHS has adapted these Zero Suicide Academies to take place over several shorter meetings that span 6 weeks to 3 months.
▪ UHS provided Riveredge with a 3-day training of trainers for the AMSR protocol (https://zerosuicideinstitute.com/amsr).
  – Over the following 2 years, Riveredge AMSR trainers then delivered the 6.5-hour AMSR training to the entire senior hospital leadership and all the clinical and intake assessment staff.
▪ A couple of clinical staff leaders at Riveredge became certified in CBT-SP, and they trained other clinical staff to use 3-4 of the manualized sessions in their normal clinical practice for suicidal patients.
▪ Riveredge established a monthly Zero Suicide committee that includes staff from all levels of the organization.
▪ Riveredge partnered with Loyola University to host a state-wide Zero Suicide Summit to promote Zero Suicide and train other hospitals, health systems, and providers in Zero Suicide.

Culture

▪ In their first workforce survey, just prior to implementing Zero Suicide, Riveredge found that about 50% of staff did not feel comfortable asking about suicide.
  – This culture improved as they trained staff on how to assess for suicide risk.
▪ Zero Suicide fit well with Riveredge’s pre-established focus on patient safety and patient-centered care. Senior leadership at Riveredge also described suicide prevention as the organization’s ethical duty.

Clinical Practice

▪ Patients seeking care at the hospital receive an initial AMSR assessment.
  – AMSR assesses suicide risk in terms of a patient’s risk status (i.e., risk compared with peers outside and inside the hospital) and risk state (i.e., risk compared with the patient’s baseline state).
  – AMSR assessment also includes discussions addressing access to lethal means, creating safety plans, and developing a meaningful treatment plan.
▪ Nurses review the AMSR assessment results when a patient arrives in their unit.
▪ Patients are asked to fill out daily check-in forms that include items on having suicidal thoughts.
▪ Riveredge works with NAMI to have peer specialists participate in inpatient group sessions.
▪ Just prior to discharge, patients participate in a bridge appointment to review the patient’s safety plan and ensure access to medications and follow-up treatment.
  – A designated support person attends this appointment with the patient if possible.
  – Typically, a staff member within assessment and referral completes these appointments; however, Riveredge has also had interns do them, and the organization is transitioning to having a nurse do them so they can review and address any changes to medications.
▪ Within 3-days of discharge, the bridge appointment staff member calls the patient to see whether he or she attended the follow-up and to ask about emotional wellbeing and thoughts of suicide.

Infrastructure

▪ Riveredge does not have an EHR system, so they have created several forms to structure and record discussions with clients (https://zerosuicide.edc.org/evidence/outcome-story/riveredge-hospital).
▪ Riveredge regularly audits random samples of nurse practice notes and discharge risk assessments.
▪ All staff go through an annual recertification process for AMSR, which includes an online video with questions and a more in-depth review for assessment and referral staff.
▪ Riveredge has continuously invested in assessing and implementing anti-ligature building features.

Sustainability Themes:

Funding Sources

▪ Zero Suicide is paid for internally by Riveredge and other UHS hospitals as part of core work the facility does.
▪ UHS covered the initial cost of training trainers for AMSR, but Riveredge has covered the cost of training several hundred of their remaining staff.
▪ Riveredge does not bill for specific services because it has daily contracted rates with insurers.
▪ Peer specialists are paid for by NAMI, and they work with multiple hospitals in the area.
▪ The CEO is committed to Zero Suicide and works with the Chief Financial Officer to find funding as needed.
▪ UHS acknowledged that value-based purchasing or pay for performance could help support hospitals in implementing Zero Suicide; however, health insurers have not typically implemented these payment approaches with inpatient psychiatric hospitals.

One-Time and Ongoing Costs

▪ Riveredge pays for one full-time equivalent nurse salary for bridge appointments and follow-up calls.
▪ Initial AMSR training of all staff was a substantial cost of time. The ongoing cost is an additional day of new-hire orientation training per person.
▪ As some AMSR trainers have left the company, Riveredge needed to train new trainers.
▪ Other trainings and refreshers are integrated with monthly staff meetings.

Cost Savings

▪ Riveredge’s Zero Suicide activities offer potential cost savings to health insurers and the community by helping patients access follow-up care and by reducing hospital readmission rates by 17%-21%.

Other Drivers of Sustainability

▪ Riveredge has been viewed as a leader of Zero Suicide within its community. Its work has been showcased to other health systems and the state legislature in Illinois.
▪ Sharing outcome stories and statistics with staff has given the workforce pride in what they are doing.
▪ Riveredge partners with Loyola University to help train nursing students in Zero Suicide activities.

Greatest Challenges:

▪ The CCO, who was the main champion for Zero Suicide, recently left Riveredge. Riveredge has been able to sustain Zero Suicide despite this loss because the CEO and other senior leaders are committed to Zero Suicide. They are in the process of establishing two directors (for nursing and clinical education) to lead the work.
▪ Not having an EHR has made it difficult to track more detailed process measures. Providers are also unable to access and review charts remotely, which has been challenging with the current pandemic.
▪ Riveredge has not been able to track whether suicide deaths occur between discharge and follow-up.
▪ Joint Commission established a requirement to use an evidence-based suicide assessment, and AMSR is evidence-informed but not yet evidence-based.
  – UHS received permission from Joint Commission to use AMSR if they studied the evidence of it, which UHS is currently doing in one of its facilities in Nashville, Tennessee.
  – Because UHS rolled out AMSR and Zero Suicide together, some facilities opted not to participate because they could still be compliant with Joint Commission requirements by implementing the C-SSRS, which does not require any formal training to use.

## Case Study Summary: Avera Health

Site Overview: Avera Health is an integrated Catholic health system serving urban and rural communities in South Dakota, Minnesota, Iowa, Nebraska, and North Dakota. Their Behavioral Health Service Line, or their governing group of all their behavioral health clinics and services, decided to support the implementation of Zero Suicide starting in 2016. It has since expanded into primary care and emergency department settings as well.

Staff Interviewed: Clinical VP of Avera Behavioral Health Service Line, Assistant VP of Avera Behavioral Health Services, Clinical Manager of the Zero Suicide Steering Committee and Psychiatric Nurse Practitioner at Avera McKennan Behavioral Health Center, Clinical Behavioral Health Tech Educator at Avera McKennan Behavioral Health Center, previous Clinical Nurse Educator and current Nursing Manager at Avera McKennan Behavioral Health Center, Avera Zero Suicide Steering Committee

Timeframe of Discussions: December 4, 2020 - December 17, 2020

Implementation Themes:

Adoption/Early Implementation

▪ Senior behavioral health leaders from Avera and the Helpline Center in South Dakota attended a Zero Suicide Academy together. They have since worked to establish Zero Suicide within their organization and community.
▪ Avera Behavioral Health Service Line hosted a Zero Suicide kickoff meeting to establish buy-in among providers, discuss the importance of preventing suicide, and discuss screening for suicide.
▪ Avera leaders decided to begin implementation of Zero Suicide within the behavioral health services so that they could establish evidence and a team of experts before engaging other departments.
▪ A survey of staff attitudes and educational needs around suicide prevention was conducted.
▪ Question, Persuade, Refer (QPR) training (~90 minutes) was offered to all nonclinical staff, and Question, Persuade, Refer, Treat (QPRT) training (~8 hours) was offered to all clinical staff.
▪ QPR and QPRT was later substituted with an online suicide prevention training developed by Avera and B-CBT training for clinical staff.
▪ Direct care providers in behavioral health were also trained in developing CRPs and discussing lethal means safety.

Culture

▪ There was initial pushback regarding the possibility of achieving zero suicide deaths; however, striving for zero suicide deaths was compared with the common goal of striving for zero medical errors.
▪ A culture shift happened once providers started seeing the impact on their patients and once there was data showing improvements in patient outcomes and reductions in hospitalizations.
▪ To maintain the culture change, new-hires in behavioral health are mentored over 4-6 weeks so that they can learn to assess and treat suicidality. Staff also complete an annual suicide-risk training.

Clinical Practice

▪ All behavioral health patients are screened at each visit with the PHQ-9 and, if suicidal, the C-SSRS.
▪ Primary care patients are similarly screened annually or when presenting with a behavioral health condition.
▪ The emergency departments screen all patients aged 13-17 presenting with a behavioral health concern with the Ask Suicide Screening Questions, and all adult patients with the Patient Safety Screener-3.
▪ Behavioral health patients who are suicidal receive lethal means counseling and a CRP, a safety plan developed using B-CBT concepts.
▪ Patients in primary care or the emergency department are connected to behavioral health services in one of three ways:
  – An integrated behavioral health provider, if available at the facility.
  – An e-triage counselor, if available within the region, who provides a diagnosis and referral.
  – A level of care assessment, available 24-7, and referral to behavioral health services.
  – Each of these services involves an assessment of lethal means.
▪ Adult patients discharged from a psychiatric hospitalization receive follow-up phone calls.
  – Avera has partnered with the Helpline Center to provide follow-up calls in South Dakota.
  – Avera also has a behavioral health navigator to provide follow-up to patients who do not meet criteria for the Helpline Center program.

Infrastructure

▪ In their EHR, Avera tracks whether patients receive a PHQ-9, a C-SSRS if suicidal, a safety plan or CRP, and lethal means counseling.
▪ These process measures are tracked on a dashboard available to providers, and clinical managers are automatically sent reports each day on how their team is doing with screening.
▪ Avera is in the process of establishing a flag for those who have attempted suicide in the past 2 years and establishing an automatic notification to outpatient providers if their patient is hospitalized.
▪ Currently, a scanned image of the CRP card is uploaded to a patient’s EHR.
▪ Avera has partnered with South Dakota to learn which patients died by suicide, and they found that some had never received behavioral health services.

Sustainability Themes:

Funding Sources

▪ Avera partnered with the Helpline Center to offer the QPR and QPRT training. The Helpline had a grant to cover the cost of the trainers.
▪ Avera paid for the development of their own short suicide-risk training, B-CBT training, and for one staff to become a B-CBT trainer.
▪ Follow-up calls with the Helpline Center are currently covered under a SAMHSA COVID-19 grant.
▪ Avera has an annual behavioral health fundraiser, which pays for their behavioral health navigator.
▪ In some locations, Avera was able to use a SAMHSA SBIRT grant to help pay for materials (e.g., tablets) for screening in primary care clinics, and for a counselor’s time to help with the brief intervention and referrals.
  – Providers do not bill insurance for SBIRT unless the patient is seen by an integrated therapist.
▪ Avera received a HRSA grant for e-triage services.
▪ Avera is becoming an ACO, so the reduction in rehospitalizations among suicide-risk patients provides additional financial benefits to the health system.

Cost Savings

▪ Avera has seen a 45% decrease in rehospitalization among patients with suicidal ideation.

Other Drivers of Sustainability

▪ The Joint Commission’s screening standards have helped sustain suicide screening in the hospital.
▪ Having data to show improvements in patient outcomes and to give providers feedback has helped sustain the work and get buy-in from leaders and providers across the organization.
▪ There is a national Zero Suicide listserv that has allowed Avera to learn from other health systems that are trying to implement and sustain Zero Suicide.
▪ Avera has involved people with experience related to suicide loss in their Zero Suicide committee and their ongoing trainings and events. This has helped provide more insight and meaning to their work.

Greatest Challenges:

▪ Continuity of care across health systems and settings is an ongoing challenge. Avera is trying to address this by using behavioral health navigators and by encouraging the implementation of Zero Suicide among other providers in the community.
▪ Avera’s legal team had concerns about handing out gun locks to patients. Instead of providing gun locks, providers share information on how to store guns safely. Many family members of patients seek out this information.
▪ Avera switched its inpatient program protocol to CRPs on small cards instead of safety plan forms. In post-discharge follow-up calls, staff have seen an increase in the number of patients using and maintaining their CRPs.