# References

1 Mattson CL. Trends and Geographic Patterns in Drug and Synthetic Opioid Overdose Deaths--United States, 2013-2019. MMWR. 2021; 70. doi:10.15585/mmwr.mm7006a4.
2 Ahmad F, Rossen L, Sutton P. Provisional Drug Overdose Death Counts. National Center for Health Statistics; 2020. https://www.cdc.gov/nchs/nvss/vsrr/drug-overdose-data.htm.
3 Baumgartner JC, Radley DC. The Spike in Drug Overdose Deaths During the COVID-19 Pandemic and Policy Options to Move Forward. Commonwealth Fund; 2021. doi:10.26099/gyf5-3z49.
4 Weiner SG, Baker O, Bernson D, Schuur JD. One-Year Mortality of Patients After Emergency Department Treatment for Nonfatal Opioid Overdose. Ann Emerg Med. Published online June 19, 2019. doi:10.1016/j.annemergmed.2019.04.020.
5 D’Onofrio G, O’Connor PG, Pantalon MV, . Emergency department-initiated buprenorphine/naloxone treatment for opioid dependence: A randomized clinical trial. JAMA. 2015; 313(16): 1636–1644. doi:10.1001/jama.2015.3474.25919527
6 National Academies of Sciences, Engineering, and Medicine. Medications for Opioid Use Disorder Save Lives. National Academies Press; 2019. 10.17226/25310.
7 Mattick RP, Breen C, Kimber J, Davoli M. Buprenorphine maintenance versus placebo or methadone maintenance for opioid dependence. Cochrane Database of Systematic Reviews. 2014; (2). doi:10.1002/14651858.CD002207.pub4.
8 Mattick RP, Breen C, Kimber J, Davoli M. Methadone maintenance therapy versus no opioid replacement therapy for opioid dependence. Cochr Database Syst Rev. 2009; 2009(3): CD002209.
9 Houry DE, Haegerich TM, Vivolo-Kantor A. Opportunities for Prevention and Intervention of Opioid Overdose in the Emergency Department. Annals of Emergency Medicine. 2018; 71(6): 688–690. doi:10.1016/j.annemergmed.2018.01.052.29523371
10 Howard B. Treating opioid addiction in the emergency department. AAMC. Published May 14, 2019. Accessed June 8, 2021. https://www.aamc.org/news-insights/treating-opioid-addiction-emergency-department.
11 Centers for Disease Control and Prevention. 2018 Annual Surveillance Report of Drug-Related Risks and Outcomes- United States. Surveilllance Special Report, Centers for Disease Control and Prevention, U.S. Department of Health and Human Services; 2018. Accessed May 11, 2021. https://www.cdc.gov/drugoverdose/pdf/pubs/2018-cdc-drug-surveillance-report.pdf.
12 Honein MA, Boyle C, Redfield RR. Public Health Surveillance of Prenatal Opioid Exposure in Mothers and Infants. Pediatrics. 2019; 143(3). doi:10.1542/peds.2018-3801.
13 Wu L-T, Zhu H, Swartz MS. Treatment utilization among persons with opioid use disorder in the United States. Drug Alcohol Depend. 2016; 169: 117–127. doi:10.1016/j.drugalcdep.2016.10.015.27810654
14 Mojtabai R, Mauro C, Wall MM, Barry CL, Olfson M. Medication Treatment for Opioid Use Disorders in Substance Use Treatment Facilities. Health Affairs. 2019; 38(1): 14–23. doi:10.1377/hlthaff.2018.05162.30615514
15 Hadland SE, Bagley SM, Rodean J, . Receipt of Timely Addiction Treatment and Association of Early Medication Treatment With Retention in Care Among Youths With Opioid Use Disorder. JAMA pediatrics. 2018; 172(11): 1029–1037.30208470
16 Thomas CP, Ritter GA, Harris AHS, Garnick DW, Freedman KI, Herbert B. Applying American Society of Addiction Medicine Performance Measures in Commercial Health Insurance and Services Data. Journal of Addiction Medicine. 2018; 12(4): 287–294. doi:10.1097/ADM.0000000000000408.29601307
17 Bagley SM, Hadland SE, Carney BL, Saitz R. Addressing Stigma in Medication Treatment of Adolescents With Opioid Use Disorder. Journal of Addiction Medicine. 2017; 11(6): 415–416. doi:10.1097/ADM.0000000000000348.28767537
18 Mojtabai R, Mauro C, Wall MM, Barry CL, Olfson M. Medication Treatment for Opioid Use Disorders in Substance Use Treatment Facilities. Health Affairs. 2019; 38(1): 14–23. doi:10.1377/hlthaff.2018.05162.30615514
19 Wakeman SE, Rich JD. Barriers to Medications for Addiction Treatment: How Stigma Kills. Substance Use & Misuse. 2018; 53(2): 330–333. doi:10.1080/10826084.2017.1363238.28961017
20 Substance Abuse and Mental Health Services Administration. Key Substance Use and Mental Health Indicators in the United States: Results from the 2019 National Survey on Drug Use and Health. Center for Behavioral Health Statistics and Quality, Substance Abuse and Mental Health Services Administration (HHS Publication No. PEP20-07-01-001, NSDUH Series H-55); 2020. https://www.samhsa.gov/data/.
21 Bart G. Maintenance Medication for Opiate Addiction: The Foundation of Recovery. Journal of Addictive Diseases. 2012; 31(3): 207–225. doi:10.1080/10550887.2012.694598.22873183
22 Schackman BR, Leff JA, Polsky D, Moore BA, Fiellin DA. Cost-effectiveness of long-term outpatient buprenorphine-naloxone treatment for opioid dependence in primary care. Journal of General Internal Medicine. 2012; 27(6): 669–676. doi:10.1007/s11606-011-1962-8.22215271
23 Thomas CP, Fullerton CA, Kim M, . Medication-assisted treatment with buprenorphine: Assessing the evidence. Psychiatric Services. 2014; 65(2): 158–170. doi:10.1176/appi.ps.201300256.24247147
24 Volkow ND, Frieden TR, Hyde PS, Cha SS. Medication-assisted therapies--Tackling the opioid-overdose epidemic. New England Journal of Medicine. 2014; 370(22): 2063–2066. doi:10.1056/NEJMp1402780.24758595
25 Fullerton CA, Kim M, Thomas CP, . Medication-assisted treatment with methadone: Assessing the evidence. Psychiatr Serv. 2014; 65(2): 146–157. doi:10.1176/appi.ps.201300235.24248468
26 Gastfriend DR. Intramuscular extended-release naltrexone: Current evidence: Intramuscular extended-release naltrexone. Annals of the New York Academy of Sciences. 2011; 1216(1): 144–166. doi:10.1111/j.1749-6632.2010.05900.x.21272018
27 Kampman K, Jarvis M. American Society of Addiction Medicine (ASAM) National Practice Guideline for the Use of Medications in the Treatment of Addiction Involving Opioid Use. J Addict Med. 2015; 9(5): 358–367. doi:10.1097/ADM.0000000000000166.26406300
28 Parran TV, Adelman CA, Merkin B, . Long-term outcomes of office-based buprenorphine/naloxone maintenance therapy. Drug and Alcohol Dependence. 2010; 106(1): 56–60. doi:10.1016/j.drugalcdep.2009.07.013.19717249
29 Pierce M, Bird SM, Hickman M, . Impact of treatment for opioid dependence on fatal drug-related poisoning: A national cohort study in England. Addiction. 2016; 111(2): 298–308. doi:10.1111/add.13193.26452239
30 Reif S, Horgan CM, Hodgkin D, Matteucci A-M, Creedon TB, Stewart MT. Access to Addiction Pharmacotherapy in Private Health Plans. Journal of Substance Abuse Treatment. 2016; 66: 23–29. doi:10.1016/j.jsat.2016.03.001.27211993
31 National Institute on Drug Abuse. Principles of Drug Addiction Treatment. National Institute of Health, U.S. Department of Health and Human Services; 2012. Accessed May 11, 2021. https://www.drugabuse.gov/sites/default/files/podat_1.pdf.
32 Substance Abuse and Mental Health Services Administration. Clinical Guidelines for the Use of Buprenorphine in the Treatment of Opioid Addiction. Substance Abuse and Mental Health Services Administration; 2004. Accessed May 11, 2021. http://www.ncbi.nlm.nih.gov/books/NBK64245/.
33 Substance Abuse and Mental Health Services Administration. National Survey on Drug Use and Health: Summary of Methodological Studies, 1971-2014. Substance Abuse and Mental Health Services Administration; 2014. Accessed May 11, 2021. http://www.ncbi.nlm.nih.gov/books/NBK519735/.
34 Clark RE, Baxter JD, Barton BA, Aweh G, O’Connell E, Fisher WH. Limiting the Duration of Medication Assisted Treatment for Opioid Addiction: Will New State Policies Help or Hurt? UMass Med. Published online 2014. doi:10.13028/FN5E-VJ16.
35 Clark RE, Baxter JD, Aweh G, O’Connell E, Fisher WH, Barton BA. Risk Factors for Relapse and Higher Costs Among Medicaid Members with Opioid Dependence or Abuse: Opioid Agonists, Comorbidities, and Treatment History. Journal of Substance Abuse Treatment. 2015; 57: 75–80. doi:10.1016/j.jsat.2015.05.001.25997674
36 U.S. Congress. Drug Addiction Treatment Act. 2000.
37 U.S. Congress. Office of National Drug Control Policy Reauthorization Act. 2006. Retrieved from https://advance-lexis-com.resources.library.brandeis.edu/api/document?collection=statutes-legislation&id=urn:contentItem:4R1F-2H20-0019-T1G3-00000-00&context=1516831.
38 42 C.F.R. § 8.610.
39 U.S. Congress. Comprehensive Addiction and Recovery Act. 2016.
40 U.S. Congress. Substance Use-Disorder Prevention That Promotes Opioid Recovery and Treatment for Patients and Communities Act. 2018.
41 HHS News Division. HHS Releases New Buprenorphine Practice Guidelines, Expanding Access to Treatment for Opioid Use Disorder. HHS.gov. Published 2021. Accessed May 6, 2021. https://www.hhs.gov/about/news/2021/04/27/hhs-releases-new-buprenorphine-practice-guidelines-expanding-access-to-treatment-for-opioid-use-disorder.html.
42 Knudsen HK. The Supply of Physicians Waivered to Prescribe Buprenorphine for Opioid Use Disorders in the United States: A State-Level Analysis. J Stud Alcohol Drugs. 2015; 76(4): 644–654. doi:10.15288/jsad.2015.76.644.26098042
43 Sigmon SC. Access to Treatment for Opioid Dependence in Rural America: Challenges and Future Directions. JAMA Psychiatry. 2014; 71(4): 359–360. doi:10.1001/jamapsychiatry.2013.4450.24500040
44 Sigmon SC. The Untapped Potential of Office-Based Buprenorphine Treatment. JAMA Psychiatry. 2015; 72(4): 395–396. doi:10.1001/jamapsychiatry.2014.2421.25671806
45 Substance Abuse and Mental Health Services Administration. Special Circumstances for Providing Buprenorphine. Published online 2019. https://www.samhsa.gov/medication-assisted-treatment/legislation-regulations-guidelines/special.
46 Thomas CP, Doyle E, Kreiner PW, . Prescribing patterns of buprenorphine waivered physicians. Drug Alcohol Depend. 2017; 181: 213–218. doi:10.1016/j.drugalcdep.2017.10.002.29096292
47 Bipartisan Policy Center. Tracking Federal Funding to Combat the Opioid Crisis. Published online March 2019. https://bipartisanpolicy.org/wp-content/uploads/2019/03/Tracking-Federal-Funding-to-Combat-the-Opioid-Crisis.pdf.
48 National Academy for State Health Policy. For New Governors: Snapshot of Major Federal Opioid Funding by State. Published online 2018. https://nashp.org/for-new-governors-snapshot-of-major-federal-opioid-funding-by-state/.
49 Substance Abuse and Mental Health Services Administration. State Targeted Response to the Opioid Crisis Grants. Funding Opportunity Announcement. Published online 2017. https://www.samhsa.gov/sites/default/files/grants/pdf/ti-17-014.pdf.
50 Massachusetts Health Policy Commission. The SHIFT-Care Challenge. Published online 2018. https://www.mass.gov/doc/hpc-shift-care-challenge-factsheet/download.
51 Massachusetts Health and Hospital Association. Guidelines for Medication for Addiction Treatment for Opioid Use Disorder within the Emergency Department. Published online 2019. http://patientcarelink.org/wp-content/uploads/2019/01/18-01-04MATguidelinesNEWFINAL.pdf.
52 Department of Drug and Alcohol Programs. Warm Hand-Off. Department of Drug and Alcohol Programs. Published 2021. Accessed June 9, 2021. https://www.ddap.pa.gov:443/Pages/Warm-Hand-Off.aspx.
53 Hospital Association of Pennsylvania. HAP’s Opioid Learning Action Network. Published 2019. https://www.haponline.org/Public-Health/Prevention-Wellness/Opioid-LAN.
54 Pennsylvania Department of Human Services. Hospital Quality Improvement Program | Follow-up treatment after ED visit for Opioid Use Disorder (OUD) Phase 2. Published May 2020. Accessed June 9, 2021. https://www.dhs.pa.gov/providers/Documents/Hospital%20Assessment%20Initiative/c_279176.pdf.
55 Pennsylvania Department of Drug and Alcohol Programs. Case Management and Clinical Services Manual.; 2020. Accessed June 9, 2021. https://www.ddap.pa.gov/Professionals/Documents/SCA%20Manuals%20and%20incorporated%20documents/2020-25%20Case_Mgt_and_Clinical_Srvcs_FINAL.pdf.
56 Stewart MT, Thomas CP, Coulibaly N. Environmental Scan: Emergency Department Interventions for Opioid Use Disorder. 2020.
57 Jakubowski A, Fox A. Defining Low-threshold Buprenorphine Treatment. Journal of Addiction Medicine. 2020; 14(2): 95–98. doi:10.1097/ADM.0000000000000555.31567596
58 Sullivan RW, Szczesniak LM, Wojcik SM. Bridge clinic buprenorphine program decreases emergency department visits. Journal of Substance Abuse Treatment. 2021; 130: 108410. doi:10.1016/j.jsat.2021.108410.34118702
59 Ritchie J, Spencer L. Qualitative data analysis for applied policy research. In: Bryman A, Burgess R, eds. Analyzing Qualitative Data. Routledge. 1994: 173–194.
60 Stewart MT, Coulibaly N, Schwartz D, Dey J, Thomas CP. Emergency department-based efforts to offer medication treatment for opioid use disorder: What can we learn from current approaches? Journal of Substance Abuse Treatment. 2021; Forthcoming.
61 Yin R. Case Study Research: Design and Methods. Fifth ed.; 2014.
62 Substance Abuse and Mental Health Services Administration. Medication-Assisted Treatment, Physician, and Program Data.
63 Centers for Disease Control and Prevention. Opioid Overdoses Treated in Emergency Departments Identify opportunities for action. Published online 2018. https://www.cdc.gov/vitalsigns/pdf/2018-03-vitalsigns.pdf.
64 National Institute on Drug Abuse. Initiating Buprenorphine Treatment in the Emergency Department. National Institute on Drug Abuse. Published 2019. Accessed June 9, 2021. https://www.drugabuse.gov/nidamed-medical-health-professionals/discipline-specific-resources/emergency-physicians-first-responders/initiating-buprenorphine-treatment-in-emergency-department.
65 D’Onofrio G, Chawarski MC, O’Connor PG, . Emergency department-initiated buprenorphine for opioid dependence with continuation in primary care: Outcomes during and after intervention. J GEN INTERN MED. 2017; 32(6): 660–666. doi:10.1007/s11606-017-3993-2.28194688
66 Busch SH, Fiellin DA, Chawarski MC, . Cost-effectiveness of emergency department-initiated treatment for opioid dependence. Addiction. 2017; 112(11): 2002–2010. doi:10.1111/add.13900.28815789
67 Sullivan RW, Szczesniak LM, Wojcik SM. Bridge clinic buprenorphine program decreases emergency department visits. Journal of Substance Abuse Treatment. 2021; 130. doi:10.1016/j.jsat.2021.108410.
68 Dunkley CA, Carpenter JE, Murray BP, . Retrospective Review of a Novel Approach to Buprenorphine Induction in the Emergency Department. Journal of Emergency Medicine. 2019; 57(2): 181–186. doi:10.1016/j.jemermed.2019.03.029.31060846
69 White WJ. Peer-Based Addiction Recovery Support: History, Theory, Practice, and Scientific Evaluation. Great Lakes Addiction Technology Transfer Center. 2009; 10(5): 54–59.
70 Goedel WC, Marshall BDL, Samuels EA, . Randomised clinical trial of an emergency department-based peer recovery support intervention to increase treatment uptake and reduce recurrent overdose among individuals at high risk for opioid overdose: study protocol for the navigator trial. BMJ Open. 2019; 9(11): e032052. doi:10.1136/bmjopen-2019-032052.
71 Waye KM, Goyer J, Dettor D, . Implementing peer recovery services for overdose prevention in Rhode Island: An examination of two outreach-based approaches. Addictive Behaviors. 2019; 89: 85–91. doi:10.1016/j.addbeh.2018.09.027.30278306
72 Samuels EA, McDonald JV, McCormick M, Koziol J, Friedman C, Alexander-Scott N. Emergency department and hospital care for opioid use disorder: Implementation of statewide standards in Rhode Island, 2017-2018. Am J Public Health. 2018; 109(2): 263–266. doi:10.2105/AJPH.2018.304847.30571304
73 Samuels EA, Baird J, Yang ES, Mello MJ. Adoption and utilization of an emergency department naloxone distribution and peer recovery coach consultation program. Academic Emergency Medicine. 2019; 26(2): 160–173. doi:10.1111/acem.13545.30074673
74 Devries J, Rafie S, Ajayi TA, Kreshak A, Edmonds KP. Results of a Naloxone Screening Quality-Improvement Project in an Academic Emergency Department. Journal of Emergency Medicine. 2019; 56(4): 378–385. doi:10.1016/j.jemermed.2018.12.029.30770141
75 Kestler A, Buxton J, Meckling G, . Factors Associated With Participation in an Emergency Department–Based Take-Home Naloxone Program for At-Risk Opioid Users. Annals of Emergency Medicine. 2017; 69(3): 340–346. doi:10.1016/j.annemergmed.2016.07.027.27745764
76 O’Brien DC, Dabbs D, Dong K, Veugelers PJ, Hyshka E. Patient characteristics associated with being offered take home naloxone in a busy, urban emergency department: a retrospective chart review. BMC Health Serv Res. 2019; 19(1): 632. doi:10.1186/s12913-019-4469-3.31488142
77 Gunn AH, Smothers ZPW, Schramm-Sapyta N, Freiermuth CE, MacEachern M, Muzyk AJ. The Emergency Department as an Opportunity for Naloxone Distribution. West J Emerg Med. 2018; 19(6): 1036–1042. doi:10.5811/westjem.2018.8.38829.30429939
78 Freiermuth C, Harger N, Ancona R, Ryan S, Ruffner A, Lyons M. 331 Implementation of a Standing Order Take-Home Naloxone Initiative in the Emergency Department. Annals of Emergency Medicine. 2018; 72(4): S131. doi:10.1016/j.annemergmed.2018.08.336.
79 Dwyer K, Walley AY, Langlois BK, . Opioid Education and Nasal Naloxone Rescue Kits in the Emergency Department. West J Emerg Med. 2015; 16(3): 381–384. doi:10.5811/westjem.2015.2.24909.25987910
80 Watson DP, Brucker K, McGuire A, . Replication of an emergency department-based recovery coaching intervention and pilot testing of pragmatic trial protocols within the context of Indiana’s Opioid State Targeted Response plan. Journal of Substance Abuse Treatment. 2020; 108: 88–94. doi:10.1016/j.jsat.2019.06.002.31200985
81 D’Onofrio G, Edelman EJ, Hawk KF, . Implementation facilitation to promote emergency department-initiated buprenorphine for opioid use disorder: Protocol for a hybrid type III effectiveness-implementation study (Project ED HEALTH). Implementation Science. 2019; 14(1): 48. doi:10.1186/s13012-019-0891-5.31064390
82 Brooklyn JR, Sigmon SC. Vermont Hub-and-Spoke Model of Care for Opioid Use Disorder: Development, Implementation, and Impact. J Addict Med. 2017; 11(4): 286–292. doi:10.1097/ADM.0000000000000310.28379862
83 American College of Emergency Physicians Clinical Policies Subcommittee on Opioids. Clinical Policy: Critical Issues Related to Opioids in Adult Patients Presenting to the Emergency Department. Published online 2020. https://www.acep.org/globalassets/sites/acep/media/clinical-policies/cp-opiods-draft.pdf.
84 National Quality Forum. Opioids and Opioid Use Disorder: An Environmental Scan of Quality Measures. Published online 2019. https://www.qualityforum.org/Publications/2019/09/Opioid_and_Opioid_Use_Disorder_Final_Environmental_Scan.aspx.
85 Madras BK, Ahmad NJ, Wen J, Sharfstein J, & the Prevention, Treatment, and Recovery Working Group of the Action Collaborative on Countering the U.S. Opioid Epidemic, Epidemic and RWG of the AC on C the USO. Improving Access to Evidence-Based Medical Treatment for Opioid Use Disorder: Strategies to Address Key Barriers Within the Treatment System. NAM Perspectives. Published online April 27, 2020. doi:10.31478/202004b.
86 Witte TH, Jaiswal J, Mumba MN, Mugoya GC. Stigma Surrounding the Use of Medically Assisted Treatment for Opioid Use Disorder. Substance Use & Misuse. Published online 2021. Accessed June 14, 2021. https://www.tandfonline.com/doi/abs/10.1080/10826084.2021.1936051?journalCode=isum20.
87 Ram A, Chisolm MS. The Time is Now: Improving Substance Abuse Training in Medical Schools. Acad Psychiatry. 2016; 40(3): 454–460. doi:10.1007/s40596-015-0314-0.25749922
88 Mackey K, Veazie S, Anderson J, Bourne D, Peterson K. Barriers and Facilitators to the Use of Medications for Opioid Use Disorder: A Rapid Review. J Gen Intern Med. 2020; 35(Suppl 3): 954–963. doi:10.1007/s11606-020-06257-4.33145687