# Acknowledgements

Brandeis University prepared this report under contract to the Office of the Assistant Secretary for Planning and Evaluation (ASPE), U.S. Department of Health and Human Services (HHS) (HHSP233201600012I 75P00119F37001). The authors appreciate the guidance of Judith Dey and Daniel Schwartz (ASPE). We are indebted to and thank the many individuals from the emergency departments included as case studies for sharing their thoughts and experiences in designing and implementing efforts to address opioid use disorder. We appreciate input from experts who shared information with us including Drs. D’Onofrio, Herring, Kolodny, Lewis, McCormack, Peronne, Wakeman and Watson. We thank Amanda Myers and Neto Coulibaly for research assistance.