# Executive summary

## Background

The United States is facing a crisis of opioid overdose deaths. More than 70,000 people died from a drug overdose in 2019, and approximately 49,000, or 70.6 percent of those deaths, involved opioids.^1^ If current trends persist, 2020 drug overdose deaths may exceed 90,000 people^2^ the highest number ever recorded in the United States.^3^

For many individuals with opioid use disorder (OUD), initial contact with the health system occurs in the emergency department (ED) while experiencing an overdose or withdrawal symptoms. However, mortality after ED visits for opioid overdose is high: one study found that one in 20 patients treated for a non-fatal opioid overdose in an ED died within one year of their visit, one-fifth of them within one month of the visit.^4^ One approach to address the opioid crisis is to expand treatment access through initiating treatment in the ED and linking to follow-up care. This report describes existing ED-based interventions for OUD and their evidence base; identifies key components of ED-based models to treat OUD; and summarizes findings across five case studies of ED-based OUD treatment programs regarding program structure, key components, barriers, and facilitators, to identify lessons for providers and policymakers.

## Methods

Information for this report comes from three sources: a literature review, interviews with experts, and case studies of five ED OUD programs. Case studies were selected to represent successful programs with varied models and structures (e.g., health system-based, state-based, individual ED) and a range of size, urban/rural area, and region. Data collection and analysis were designed to generate actionable information for model replication. Case studies include Denver Health and Hospital Authority, Denver Colorado; Marshall Medical Center, Placerville, California; Highland Hospital, Alameda Health System, Oakland California; NY MATTERS, Buffalo, New York; and Anchor ED, Providence, Rhode Island. Virtual site visits were conducted over video conference between February and May 2021. They consisted of document review and interviews with up to nine key program staff and stakeholders from each site. Interview topics included the history of the program, financing and motivation, key components, metrics used to monitor and measure success, barriers, facilitators of success, and sustainability outlook. Interviews were analyzed and summarized by theme using a framework analysis approach.

## Findings

ED-based efforts to address OUD are developing across the United States and take a range of approaches. Approaches include providing ED-based initiation of medications for opioid use disorder (MOUD) and connecting patients with ongoing care, directly referring patients to community providers for OUD treatment, and offering harm reduction services such as overdose education and take-home naloxone for emergency use. The variation in approach is driven in part by ED clinicians’ and other leaders’ understanding about their role in addressing OUD, and by the local treatment environment and resources. For example, some providers see the ED as a critical place to reach individuals with OUD, while other providers see OUD as a chronic condition and outside the scope of ED practice.

### Evidence base for ED-based models to treat OUD

Systematic evidence for the effectiveness of ED-based efforts to treat OUD is limited but growing.^5–8^ A Yale University randomized trial in 2015 compared ED-initiated buprenorphine to brief intervention and referral, and to referral alone. It showed that initiating buprenorphine in the ED is feasible and effective, resulting in follow-up treatment, at least in the short-term.^5^ Several observational studies measuring process metrics and limited outcome measures suggest ED-initiated MOUD is effective in helping patients engage in outpatient treatment.^5–8^ Literature and interviews indicate that over half of initiated patients are engaged in treatment at 30 days or longer in some programs. Studies are currently underway examining the role of different staffing patterns and additional longer-term outcomes. For programs studied here, metrics for examining program effectiveness are primarily process measures (initiation and short-term and longer-term engagement rates), but at least one program monitors overdose rates.

### Factors motivating the development of ED-based interventions for OUD

Most often, programs are started by highly motivated clinicians, championing an approach tailored to the hospital, community resources, and patient mix. Across the five case studies described in this report, all were started by passionate ED providers who saw the potential for evidence-based treatment and recovery starting in the ED, and wanted to do more for people with OUD. ED staff report finding the work very rewarding. Several interviewees described providing MOUD as some of the most fulfilling work they do in the ED. Interviewees also noted the role of the ED-based programs in reducing stigma in the ED and embedding OUD treatment as a core component of ED services.

### Key components of ED-based models to treat OUD

Because programs are relatively new and developed independently across the country, there is variation in structure and treatment approaches. Key components of ED-based OUD treatment efforts include patient identification, treatment approaches, program structure, relationships with community programs, and financing. Programs vary across these components based on implementation choices, the hospital setting, and available resources. Despite these variations, programs similarly focus on making treatment more accessible by lowering barriers such as those related to drug testing requirements and the use of multiple substances. ED-based efforts to treat OUD work well when they have reliable and accessible referral sources and the ability to provide MOUD. Ongoing treatment may be provided by hospital-based bridge or outpatient clinic, affiliated bridge clinic or community-based organizations. Some ED-based programs use peer navigators with lived experience, while others use navigators from the community who are not necessarily in recovery. Programs described in the literature and all of the case studies recognize the importance of peers or other support staff members to assist patients in navigating their care. Reimbursement is available for aspects of ED-based OUD treatment, but some services are not consistently covered by insurance (e.g., navigators).

All of the case study programs originated with grant funding or have used grants to cover some services, and most continue to be funded at least in part through grants. All plan to continue operation, though reliance on grant funding remains a risk to program sustainability. Three of the five programs studied have expanded, or are planning to expand, to address other substance use disorders (SUDs) because of the program’s perceived effectiveness with OUD and because the notion that helping more patients may improve program efficiency. In particular, identification and treatment of individuals with alcohol and stimulant use disorders are targets for expanding programs.

### Barriers and facilitators

Barriers to implementing ED OUD programs include the stigma associated with OUD and MOUD; limited availability of reliable outpatient treatment and needed recovery supports; a lack of information and knowledge about OUD treatment; provider concerns about ED workflow; patients’ lack of insurance; inadequate program funding, particularly for the work of navigators; and policies that limit buprenorphine prescribing.

Facilitators for program implementation include having a patient-centered, low-barrier approach that promotes the uptake of treatment; a passionate champion and expert in OUD treatment; a strong structure to facilitate communication across partners and seamless treatment; the ability to track performance; and adequate funding from sustainable sources.

## Conclusions and policy implications

Several implications for policy and practice emerged from this work. ED-based MOUD is feasible and effective in helping patients engage in treatment. Building on the strength of current models, efforts are needed to make it easy for patients to obtain treatment, as they are often ready when they present to the ED. Actions to facilitate ED-initiated treatment and engagement in ongoing care include supporting the availability of treatment on demand (TOD) and 24 hour follow-up, making the culture of the ED welcoming to all patients, funding of related services such as expanding capacity for treatment in the community within days of being seen in the ED, and supporting recovery services such as housing and transportation.

Opportunities exist to facilitate program development by offering additional venues for learning collaboratives, including sharing models, challenges, and successes. These venues can also provide a forum for developing and testing guidelines and standardized measures and tools to evaluate impact more effectively. They also can serve as an important vehicle for dissemination. One program studied has already considered starting an academy to train clinicians in developing and implementing ED OUD programs.

Educational efforts are warranted for providers and the community to improve awareness and knowledge about OUD treatment options and address stigma. Unfortunately, stigma occurs among ED providers and within communities generally. However, programs and subject matter experts repeatedly report that once the community is aware of the services offered through an OUD program in the ED, they are usually well accepted and supported.

Addressing the challenges of inadequate funding of ED OUD programs presents another opportunity. Programs suggested financing models that include adequate coverage for non-clinical personnel critical to the program, such as recovery navigators or peers, is key to sustainability. The Medication Assisted Treatment-Prescription Drug and Opioid Addiction (MAT-PDOA), State Targeted Response (STR) to the Opioid Crisis and State Opioid Response (SOR) grants, originating with federal funding, were instrumental in numerous cases to the early development of the programs that were studied. Once programs are beyond the pilot stage, they may become incorporated into hospital budgets. However, many must continue to seek grant funding. Payment models that address gaps in coverage and inadequate reimbursement are important to consider.

A systematic approach to identifying and assessing ED-based MOUD efforts is needed, including addressing the impact of key features, cost-effectiveness of programs, and sustainability. More in-depth analyses of variation in ED-based OUD programs would help inform best practices. Efforts to disseminate information about ED-based OUD treatment may help to expand programs beyond early, enthusiastic adopters. Studies of which patients to target, how best to identify patients for OUD treatment, and how best to support patients as they engage in outpatient treatment would help ED providers implement efficient and effective programs. Systematic information on patient and provider perspectives on these programs would also help improve services.

Efforts are needed to expand the availability of low-barrier MOUD in a systematic way and to support EDs that are not early adopters in offering MOUD. Additional research on barriers EDs that have not yet started offering MOUD face and how to support and encourage ED-based MOUD initiation in EDs that are not early adopters may help expand efforts. The cases included here were early and enthusiastic adopters of ED-based MOUD initiation, but many EDs do not provide MOUD. Studies might also identify where there exist the best opportunities to expand ED-based interventions for OUD, and when to use a top-down or a bottom-up approach.

Finally, most models studied are expanding beyond the identification and treatment of OUD. Programs are using the lessons from treating OUD to identify and engage patients who have alcohol use disorder or disorders related to methamphetamine and other substances. Stimulant use is a growing national problem, and interviewees feel it is important to respond. ED-based programs can draw from the experience with OUD, although specific challenges of treatment may differ. Supporting the expansion of ED OUD programs to a wider range of SUDs is a natural step already started by ED programs.