# Acronyms

The following acronyms are used in this report and/or appendices.

ASPE: HHS Office of the Assistant Secretary for Planning and Evaluation
BHDDH: Rhode Island Department of Behavioral Healthcare, Developmental Disabilities and Hospitals
CAM: Colorado Center for Addiction Medicine
COVID-19: Novel Coronavirus
DATA: Drug Addiction Treatment Act
DHHA: Denver Health and Hospitals Authority
ED: Emergency Department
EMR: Electronic Medical Record
FDA: HHS Food and Drug Administration
FQHC: Federally Qualified Health Center
HHS: U.S. Department of Health and Human Services
HIPAA: Health Insurance Portability and Accountability Act
HIV: Human Immunodeficiency Virus
MAT-PDOA: Medication Assisted Treatment-Prescription Drug and Opioid Addiction grant
MORE: Anchor Mobile Outreach Recovery Efforts
MOUD: Medications for Opioid Use Disorder
NY MATTERS: New York Medication Assisted Treatment and Emergency Referrals
OB/GYN: Obstetrics and Gynecology
OBOT: Office-Based Opioid Treatment
OTP: Opioid Treatment Program
OUD: Opioid Use Disorder
PDMP: Prescription Drug Monitoring Program
Rx: Prescription
SAMHSA: HHS Substance Abuse and Mental Health Services Administration
SBIRT: Screening, Brief Intervention, and Referral to Treatment
SOR: State Opioid Response
STR: State Targeted Response
SUD: Substance Use Disorder
TOD: Treatment on Demand