# Discussion

## Summary of findings

Offering low-barrier ED-initiated MOUD is one strategy to achieve greater access to OUD care and has emerged as an important entryway for treatment. Systematic evidence for the effectiveness of ED-based efforts to treat OUD is limited but indicates that ED-initiated MOUD is feasible and effective for helping patients engage in outpatient treatment. ED-based efforts take a range of approaches, including ED-initiated MOUD and peer support, and have proliferated over the past several years. Programs continue to evolve.

Most often, programs were started by highly motivated clinicians, championing an approach tailored to the hospital, community resources, and patient mix. Because programs are relatively new and developed individually across the country, there is variation in structure and treatment approaches.

Key components of ED-based OUD treatment efforts include the approach to patient identification, treatment approaches, program structure, relationships with community programs, and financing. Programs vary across these components based on implementation choices, the hospital setting, and available resources. ED-based efforts to treat OUD work well when they have reliable and accessible referral sources and the ability to provide medication treatment. Programs vary in how they identify patients, but overall, lowering barriers to treatment helps patients engage and includes any path to recovery. Some programs use peer navigators who are in recovery, while others use navigators from the community who are not. Insurance reimbursement is available for aspects of ED-based OUD treatment, but most programs also rely on grant funding for services that are generally not covered by insurance (e.g., navigators). Often programs studied originated with grant funding, and some continue to be funded through grants. This is a risk to program sustainability.

Regarding sustainability, all programs identified plan to continue operation. Some are expanding to address other SUDs -- in part because of the perceived effectiveness of the program with OUD and in part because helping more patients may improve program efficiency. Most individuals interviewed noted the role of the programs in changing the culture of the ED and embedding OUD treatment as a core component of the ED.

Barriers to implementing ED-initiated MOUD programs include stigma, funding, lack of knowledge about OUD among ED providers, and lack of reliable, high-quality outpatient treatment for ongoing care. Facilitators for program implementation include having an ED champion, education of ED providers on treating patients with OUD, communication with community providers to establish referral relationships and ensure adequate follow-up, and methods to track performance.

ED-based efforts to address OUD are an important vehicle for reducing stigma around SUDs among providers, patients, and the community.

## Limitations

Although a great deal was learned through this research and discussions with program leadership and stakeholders, some limitations must be noted. First, field research was planned just prior to the emergence of the COVID-19 pandemic and the accompanying burden on hospitals and travel restrictions. All of the interviews for this project thus were conducted virtually. While interviews retained the structure and content originally planned, the investigators were unable to meet in person and tour the facilities to get an on-the-ground experience of the programs and their settings.

Established programs were purposefully selected for case studies. Our findings may not generalize to other hospitals or organizations. Although sites mentioned several barriers to offering OUD treatment in EDs, these sites overcame the barriers for the most part. Additional barriers may exist in EDs that are not yet providing ED-based OUD treatment.

## Implications for policy and practice

Because ED OUD programs often emerge from individual team efforts across many institutions, there are variations in implementation. All, however, encounter challenges of funding, resources, and stigma. Much remains to be learned from current efforts to provide guidance to nascent programs and systems interested in developing ED-based OUD interventions. Therefore, opportunities exist to facilitate program development by offering additional venues for learning collaboratives, including sharing of models, challenges, and successes. These venues can also provide a forum for developing and testing guidelines and standardized measures and tools to more effectively measure change and impact. They also can serve as an important vehicle for dissemination. One of the programs studied has already considered starting an academy to train clinicians in developing and implementing ED OUD programs.

Efforts should be made to lower barriers to patient care, making it easy for patients to start treatment, as they are often ready at the time they present to the ED. This includes both funding of services such as expanding capacity for treatment in the community within days of being seen in the ED, availability of TOD and 24-hour follow-up, and ongoing efforts to make the culture of the ED and SUD treatment more broadly welcoming to all patients.

Educational efforts are warranted for providers and the community to improve awareness and knowledge about OUD treatment options and to address stigma. Stigma occurs among providers within and beyond the ED and within the community. Programs and subject matter experts repeatedly report that once the community is aware of the services offered through an OUD program in the ED, they are usually well accepted and supported.

Addressing the challenges of inadequate funding of ED OUD programs presents another opportunity. Programs suggested financing models that include adequate coverage for non-clinical personnel critical to the program, such as recovery navigators or peer navigators, is key to sustainability. The MAT-PDOA and STR/SOR grants, originating with federal funding, were instrumental in numerous cases to the early development of the programs that were studied. Once programs are established, they may become incorporated into hospital budgets. However, many must continue to seek grant funding. Payment models, such as bundled payments, that address gaps in coverage are important to consider.

Because programs use a range of metrics for their own purposes, a systematic approach to identifying and assessing ED-based MOUD efforts is needed, including evaluating the impact of key features. Systematic information on patient and provider perspectives on these programs would help to further elicit information about improving services. Finally, additional analyses of the cost-effectiveness and sustainability of programs are needed. Many programs report that they have anecdotal information about the effectiveness of programs, but without more rigorous data on effectiveness and cost, it will be difficult to support an argument to maintain efforts, especially when grant funding is no longer available.

More research is also needed on barriers EDs that have not yet started offering MOUD face and how to support and encourage expansion of ED-based MOUD initiation in EDs that are not early adopters. The cases included here were early and enthusiastic adopters of ED-based MOUD initiation, but many EDs do not provide MOUD; studies on whether a top-down or a bottom-up approach to expanding ED-based MOUD are needed. Studies are also needed of which patients to target, how best to identify patients for OUD treatment, and how best to successfully support patients as they engage in outpatient treatment. Research on how many lives are saved and negative health outcomes and ED visits are avoided because of the availability of OUD treatment in the ED is needed and would help as EDs consider expanding access to medication for OUD. However, even without this research, key informants argue EDs have available effective treatments, and if they identify patients with OUD, they must also offer medication treatment.

Finally, most models have expanded beyond the identification and treatment of OUD. Programs have used the lessons from OUD programs to identify and engage patients who have other SUDs, particularly alcohol and stimulant use disorders. Stimulant disorders are seen as a growing national problem, and interviewees feel it is important for their programs to respond. ED-based programs can draw from the experience with OUD, although specific challenges of treatment may differ. Supporting the expansion of ED OUD programs to a wider range of SUDs is a natural step already started by ED programs.