# Findings

## Overview of ED-based efforts to address OUD

ED-based interventions for OUD are being implemented across the US

Efforts include a mix of approaches:

- Initiating medication for OUD in the ED.
- Directly referring patients from the ED to community OUD treatment.
- Engaging in harm reduction approaches including education about safer use and naloxone distribution.

ED-based efforts to address OUD are developing across the United States and take a range of approaches, including providing low-barrier^iii^ ED-based MOUD and connecting patients with ongoing care, directly referring patients to community providers for OUD treatment, and offering harm reduction efforts such as providing overdose education and naloxone as a take-home emergency medication. This variation in approach is driven in part by ED physician understandings about their role in addressing OUD. Some providers see the ED as a critical place to reach individuals with OUD, while other providers see OUD as a chronic condition outside the scope of the ED.

Within the broad categories of ED approaches to OUD, there are various key program components that may influence program reach and effectiveness. Some EDs may also engage in preventive measures, such as reducing the use of opioid medications in the ED to prevent individuals from becoming dependent; these are beyond the scope of this report.

This report focuses on ED efforts to provide MOUD and connect patients with ongoing care. ED-initiated MOUD is recommended by federal agencies,^62–64^ but programs are implemented inconsistently across the country.

## The evidence base for ED-based models to treat OUD

### Evidence of effectiveness of ED-based medication initiation

Evidence base for ED-based interventions for OUD

- A randomized trial found higher rates of treatment engagement among patients started on buprenorphine in ED than among those receiving only a referral.
- Other studies are retrospective, and lack comparison groups.
- Several studies are underway.
- Evidence is growing.

Existing evidence of the effectiveness of ED-initiated buprenorphine treatment is based on one randomized trial, a randomized pilot study, and several smaller observational studies. In the randomized trial of 329 individuals in a single hospital, ED-based initiation of buprenorphine with referral to primary care was compared to usual care approaches of referral to community treatment and brief intervention and referral. The study found higher rates of clinician-reported treatment engagement at 30 days following the ED visit among individuals randomized to the buprenorphine group compared to the referral-only or brief intervention and referral groups (78 percent vs. 37 percent and 45 percent, respectively).^5^ Among the 74 percent of patients for whom the authors were able to obtain information on past seven day drug use, the buprenorphine group reported larger declines in drug use than the other groups.^5^ There were no differences among groups in urine drug screen outcomes among the 67 percent of patients for whom this data was available. Further analyses followed 88 percent of the randomized sample to measure outcomes at two, six, and 12 months. Similar to the 30 day results, at 60 days, individuals randomized to the buprenorphine group were more likely to be engaged in treatment compared to the referral-only or brief intervention and referral groups (74 percent vs. 53 percent and 47 percent, respectively).^65^ No differences were identified in treatment engagement at six and 12 months after randomization or in secondary outcomes of drug use and HIV risk behavior among the three groups.^65^ Additional analyses of the same effort also found ED-initiated buprenorphine to be cost-effective compared to referral and to brief intervention and referral.^66^

Recent studies conducted in real-world settings demonstrated the potential impact of ED-initiated buprenorphine and referral to a Bridge Clinic. Among 269 patients with OUD diagnoses who received an initial dose of buprenorphine in the ED and completed an initial consultation with a Bridge Clinic, there was a 42 percent decrease in ED visits over the following six months.^67^ A small study of 19 individuals with OUD who received ED-initiated buprenorphine treatment found that 63 percent of patients kept their initial outpatient appointment, and 75 percent of those individuals were still engaged in treatment after 30 days and 33 percent remained engaged at six months.^68^

### Evidence of effectiveness of ED-based peer support services

Peer support services for SUD delivered in the context of EDs refers to services provided by individuals with lived SUD recovery experience. Support services provided by peer navigators^iv^ include, for example, education, assertive outreach, and assistance overcoming barriers to treatment such as transportation or childcare. Peer support services can be implemented both as part of a comprehensive program of ED-based OUD treatment that includes medication initiation and as a standalone intervention to help connect patients to outpatient treatment. There are few studies of ED-based peer support services for individuals with OUD. A randomized controlled trial of ED-based peer supports for OUD is currently underway, but results are not yet available.^70^ However, existing research shows that peer support services are feasible to implement in the ED and acceptable to patients.^71^ In an observational retrospective cohort study of peer supports in an ED, Samuels (2018) identified similar rates of initiation of medication treatment between patients working with a peer and those who were not and shorter time to treatment engagement among those with peer supports.^72^ A pre-post study of this effort using medical record review found patients are more likely to be discharged with a referral to treatment when they meet with a peer.^73^

“They were coming to the [hospital] door in the wee hours of the night; they were lining up. And we know that if you can’t get into a treatment program when you come in, your chances of coming back are really low, and the dangers of fatal overdose increase over time.”

– Recovery services administrator

“I became interested in patients struggling with substance use disorder and identifying a coherent population health strategy to address it.”

– Hospital administrator

### Evidence for ED-based harm reduction efforts

Although it is not specifically treatment, ED-based naloxone distribution is an important harm reduction function of EDs and appeared throughout the literature search. Several studies show it is feasible to distribute naloxone to patients leaving the ED and that patients are accepting of naloxone.^74–76^ However, uptake of naloxone distribution by EDs is low.^76,77^ The low uptake may be due to the additional burden to ED workflow,^77,78^ and to limited evidence of the full impact of naloxone distribution because of challenges with following patients after they leave the ED.^77^ However one study that was able to follow a small number of patients reported that 16 percent (6/37) of kits were used to reverse an overdose.^79^

### Additional efforts and studies underway

Several efforts are currently underway to more rigorously study ED-based approaches for OUD. A pragmatic multi-site cluster randomized trial is currently underway in Indiana.^80^ The ANCHOR trial of peer support for individuals presenting to EDs is underway in Rhode Island.^70^ The NIDA Clinical Trials Network is studying an implementation facilitation model to test whether it improves ED-based treatment of OUD in four urban EDs.^81^ The Massachusetts Health Policy Commission is funding an evaluation of nine hospitals’ efforts to expand ED-based treatment.^50^

Beyond these efforts, many additional ED-based programs are emerging across the country. However, because programs are often developed by individual providers and hospitals, clinicians report that their focus is on patient care rather than formally evaluating and publishing or otherwise disseminating their outcomes.

## Factors motivating the development of ED-based interventions for OUD

Beyond the unifying backdrop of tens of thousands of opioid-related deaths in the United States, additional local factors motivated the development of ED-based interventions. In all case studies, there was a champion in the ED. All five cases started with one or two providers who obtained their DATA waivers to prescribe buprenorphine and worked through the process of establishing induction protocols and developing connections to outpatient treatment for a small number of patients. Inspiration for most of these starts came from the randomized trial^5^ and the Vermont hub-and-spoke model.^82^ In some cases, the ED champion(s) had a partner champion from the hospital administration.

Many of the cases focused first on medication for treating OUD, while at least one (Anchor ED) started with a broader approach of embracing “many roads to recovery.” In most cases, an informant mentioned the desire to meet patients “where they are.” In all cases, when other staff in the ED saw first-hand the improvement in patients’ lives, the reduced number of ED visits, and the concrete help they could offer, the will to expand these programs increased dramatically. Providers expressed finding this work very rewarding. One explained, “Giving a patient with OUD, who feels very powerless, the ability to pick which clinic they want to go to, and guarantee the clinic will take them…is unbelievably empowering.”

New funding was also essential for these small initial efforts to grow. HHS Substance Abuse and Mental Health Services Administration (SAMHSA) grant programs including the MAT-PDOA and STR/SOR grants played an essential role at this juncture, often enabling the official “pilot” stage and protocol development for these programs. With additional funding from city, county, state, hospital, and private grant sources, most programs scaled to 24/7 or nearly 24/7 OUD treatment services and the models of today.

## Key components of ED-based models to treat OUD

Key components of ED-based MOUD initiation efforts were identified through literature review and key informant interviews and are described in Table 2. Both in the literature and across the case studies, programs vary widely on each component.

Patient identification. Patients may be identified when they come in for overdose, the ED may conduct screening or use some type of algorithm to identify patients, or patients may come to the ED in withdrawal and looking for help with OUD (especially if it is known in the community that the ED provides treatment). In the randomized trial of ED-initiated MOUD,^5^ 9 percent of patients were identified following an overdose, 66 percent were identified through screening, and 34 percent self-identified -- often presenting in withdrawal and seeking treatment.

According to interviewees, a program’s approach to patient identification affects MOUD uptake levels and influences the amount of work involved in encouraging patients to start MOUD. Programs that screen for OUD and ask all patients with possible OUD if they are interested in treatment will have a larger base of patients identified than those who include only patients requesting treatment. The approach to identification is also likely to influence evaluation results because programs will vary in the type of patient they identify and whether patients are likely to start treatment.

Treatment approach. Programs vary in their treatment approaches and may initiate buprenorphine treatment in the ED, send patients home with a prescription for buprenorphine for home induction, or offer a warm-handoff to a bridge clinic for initiating treatment. Bridge clinics are usually located close to the ED and may be part of the hospital system. Although bridge clinics are usually intended for short-term treatment, interviewees reported that patients could receive ongoing care there if desired.

Program structure. Program structure includes the system within which the program operates (e.g., free-standing hospital, integrated health system), where the program is based (e.g., ED, hospital behavioral health or addiction medicine department, community-based organization), the staff engaged in OUD treatment (e.g., physicians, nurses, social workers, recovery navigators), availability of these staff (e.g., hours treatment is available, navigators based in the ED or accessible through other means), and the model for coordinating care beyond the ED (e.g., hospital-based bridge clinic, warm-handoff or referral to community-based treatment).

A critical component of staffing is the use of non-clinical staff such as recovery navigators,^v^ including peer navigators. Recovery navigators are trained in engaging patients and helping them navigate through the care pathway. Recovery navigators may also work to secure additional resources or social supports if needed. The structure includes whether the recovery navigator is employed by the hospital or a community-based organization and the department where they work in the hospital (ED or other).

Table 2 Key components of ED-based interventions for OUD

Key feature | Description | Examples
Patient identification | How are patients identified in the ED as possibly needing OUD treatment? | Screening all ED patients, individual clinician identification, real-time EMR-based algorithms to flag potential cases, patient self-identification in response to community outreach or signs and pins posted throughout ED
Treatment approaches | How are OUD treatment services delivered? | Offer medication vs. only referral to community-based treatment; Medication typically used (buprenorphine vs. others); initiate in ED or provide buprenorphine take-home doses or warm-handoff to hospital-based bridge clinic
Program structure | How is the ED-based program structured (e.g., hours, staffing, coordination)? | Capacity, 24-hour services vs. shorter hours; model to support coordination (e.g., navigators embedded or available, involvement of hospital-based social workers or clinicians); how programs coordinate care beyond ED; health system includes an outpatient OTP or hospital-based bridge clinic
Relationship with community treatment programs | How does the program integrate with other community programs? | Availability of outpatient treatment in the community, the strength of connection with an outpatient partner; warm-handoff or referral to community partner; follow-up strategy with the patient and/or community partner; actively working to partner with social services to identify eligible patients
Program financing | How mature is the program, how is it financed, is it sustainable? | Individual hospital funded, a state program, federal funds

Relationship with community-based treatment programs for follow-up. To connect patients with ongoing care, EDs facilitate warm-handoffs to specialized treatment providers, including hospital-based bridge clinics and community-based outpatient providers. Interviewees emphasized that ED providers need reliable community treatment partners so that they will not have to spend a lot of time searching for outpatient treatment and will not get pushback from community treatment providers to which they refer patients.

Program financing. ED-based buprenorphine initiation is generally reimbursed by insurance. However, employing recovery navigators and other infrastructure may not be covered by insurance and frequently require additional funding. Often programs are grant-funded; many interviewees reported using SAMHSA STR/SOR funding to cover expenses associated with waiver training and employing navigators.

## Examples of how case study programs approach key components

Each case study adapted key components to the needs and resources of their health system and community. Table 3 and the descriptions below summarize the case study sites by each key component.

Patient identification. Two programs screened patients in the ED; all programs accept patients who self-identify requesting treatment, and two programs encourage self-identification by advertising the program through signs throughout the ED and pins and badges that staff wear. Highland Hospital relies entirely on patient self-identification. The Highland Hospital ED has signs that read, “If you are struggling with pills or heroin, we can start you on buprenorphine today.”

Similarly, most patients who start medication treatment through the DHHA ED come to the ED in withdrawal from opioids and seeking treatment. One interviewee at the DHHA program reported the program is “Patient-driven; patients are not really approached by doctors.” The Marshall program takes a mixed approach. An interviewee at Marshall Medical Center reported at least 50 percent of patients who start MOUD in the ED self-identify, but the hospital does screen patients for OUD, and providers will ask if patients are interested in treatment. Other programs rely entirely on individual provider discretion. For example, the Anchor ED program, which is available to 11 hospitals in Rhode Island, does not advertise to patients but conducts outreach to ED staff, reminding them that the Anchor ED services are available.

Treatment approaches. ED-based programs also vary in their approach to treating OUD in the ED. Three of the ED-based programs we examined (Denver, Marshall, Highland) focused on initiating medication in the ED using buprenorphine. The statewide programs (NY MATTERS and Anchor ED) operate differently. NY MATTERS partners with EDs that initiate patients on buprenorphine and provides the MATTERS technology and network, which allows those EDs to connect patients with ongoing community-based treatment. The Anchor ED program provides peer supports to patients in the ED. If patients are interested in medication treatment, Anchor ED will link patients to outpatient treatment that includes medication as well as treatment that does not, acknowledging that there are many paths to recovery.

Specific protocols for the initial induction of medication for OUD also vary across programs. Programs frequently develop their own protocols for treatment. While some organizations have developed guidelines to initiate OUD medication in the ED, there is no national standard for starting OUD treatment in US EDs.^83^ Some physicians find the recommended doses of buprenorphine for induction are too restrictive and low and that patients are more likely to agree to treatment if they receive medication earlier in their withdrawal experience. The American College of Emergency Physicians reports that comprehensive ED buprenorphine dosing data are not available.^83^

EDs that offer medication treatment for OUD may administer the medication in the ED or, if a patient is not yet in withdrawal, may keep the patient for several hours and then administer medication, send the patient home with the medication, or issue a prescription for the medication and instructions for taking it when withdrawal progresses.

Table 3 Case study site approaches to key components of ED OUD programs

Site | Approach
Case study site | Structure | Patient identification | Treatment approaches | Relationship with community programs | Financing^*^
Denver Health and Hospital Authority (DHHA) | Hub-and-spoke; integrated team across ED & behavioral health departments, other spokes | Patient self-identification, screening, community-based information campaign | Initiate medication in ED & receive next day appointment | Most patients are linked to care within the DHHA system | Initially federal grants, now hospital funding
Marshall Medical Center | Run by ED physician assistants, nurse practitioners, navigators | Patient self-identification, screening, signs posted in ED, community outreach | Initiate in ED and schedule follow-up appointment w/ partners | Partners w/ hospital’s outpatient SUD clinic & 4 community health centers | State & federal grants
Highland Hospital | Run by ED physicians, w/ navigators; close relationship w/ affiliated bridge clinic | Patient self-identification; signs, pins, information posted in ED, community outreach | Initiate in ED & warm-handoff to bridge clinic | Bridge clinic is an “extension” of ED | Initially grant-funded; now hospital funding
NY MATTERS | Statewide referral network & electronic platform; connects patients in ED & other settings w/ community-based treatment | Varies by partner site | Initiate in ED or provide Rx for home induction & schedule outpatient appointment | Partners with community-based outpatient treatment providers across the state; requires partners to sign Mission, Vision, Values statement | State and federal grant funding
Anchor ED | Operated by a community-based organization; connects ED patients w/ peer recovery services | Varies by hospital | Peers connect patient w/ community-based treatment and recovery resources | Partnerships with several other community organizations | Started with donations, now funded with state and federal grants

* All programs bill insurance where possible. This column refers to financing in addition to health insurance.

Program Structure. The cases we examined operated within a range of systems from rural free-standing hospital to hub-and-spoke model^vi^ in an integrated health system. The type of system in which the program operates influences how the ED connects patients with ongoing treatment. The Denver program, operating within an integrated health system and a hub-and-spoke model, was able to connect patients with an outpatient clinic in the DHHA system and did not have to establish relationships with outside community providers. Marshall Medical Center is a free-standing rural hospital, and patients are connected with either the outpatient program at the hospital or one of several community-based organizations geographically distributed across a large area. Highland Hospital connected patients to a bridge clinic that is not part of the hospital system but is located near the hospital and staffed with people who also work in the Highland ED. The key in each system is strong communication within the team and with the outpatient treatment sites.

The program structure also includes the organization that runs the program. Four of the case studies are programs led by hospital-based staff (ED providers, physician or physician assistant), and one is run by a community-based provider treatment organization. ED providers reported that sometimes the community-based organizations approach OUD differently, such as focusing less on medication treatment.

In addition to organizational structure and program leadership, program services and staffing are important aspects of program structure. All ED-based programs use support staff to help patients navigate through the ED visit and connect with continuing care. Some programs provide additional services beyond helping patients connect with ongoing care, for example, assisting patients with accessing housing services or transportation.

Three of the programs studied used navigators or peer navigators to connect patients with continuing care; one program reported using hospital social workers and behavioral health clinicians rather than navigators for this particular function. Programs vary in whether the navigators are peers with lived experience or individuals from the community who are not in recovery themselves.

Table 4 shows the role of navigators for each case study site. Navigators usually serve as a liaison with the patient, in some cases being brought in very early upon a patient’s admission to the ED to make initial contact with a patient who is deemed likely to need treatment or to follow up after a clinician has discussed treatment with a patient. Often it is the navigator that is responsible for creating an atmosphere in which patients choose to seek treatment.

Navigators may be embedded in the ED, as is in the case with Marshall and Highland, or they may be on call within minutes, as in Anchor ED’s program. Several interviewees reported that having navigators embedded in the ED, rather than on call, was more efficient and seamless. While acknowledged by all as critical to the success of ED OUD programs, it was noted that sometimes peer navigators can face barriers to working in the ED and may not always fit with the ED culture. For example, interviewees noted some peer navigators based in the ED have difficulty passing criminal background checks required to work in the hospital. Stigma among clinical staff regarding OUD was also reported to make it difficult to collaborate. Finally, respondents reported that in some cases, peers are not advocates for MOUD and instead promote abstinence-based recovery, creating challenges for clinicians who are poised to initiate MOUD.

Table 4 Role of peers and navigators by case study site

Denver Health and Hospital Authority | - Based in the behavioral health outpatient clinic; generally peer navigators.; - Help patients complete enrollment paperwork.; - Facilitate scheduling clinic appointments and arranging other services (e.g., transportation, housing, detoxification services).
Marshall Medical Center | - Based in the ED; generally peer navigators; knowledgeable about treatment system and aim to be experts in navigating the system.; - Acts as a link between patients, ED, clinic, and physicians.; - Respond to consult orders from throughout the hospital, discuss treatment options with patients.; - Link patients to the local clinic or clinics in their geographic area.; - Facilitate warm-handoffs to care.; - Follow-up with patients who receive a referral.
Highland Hospital | - Employed by the hospital and embedded in ED; generally not peers.; - Recruited from a mentoring program for underrepresented students groups (high school and college who are from the community).; - Meet with patients in the ED to take a history and assess needs/desires for treatment; report back to ED physician.; - Helps to assure that the patient’s needs are met (food, medication, etc.).; - Provides connection to social services and resources, including bridge clinic.; - Responsible for follow-up with the patient after discharge from the ED.
NY MATTERS | - The patient chooses whether they want to be connected to a peer navigator.; - If yes, the peer organization affiliated with the hospital is notified. If the hospital does not have a peer organization, the state peer organization affiliate is notified.; - Structure and responsibilities vary by hospital/organization.
Anchor ED | - Employed by the social service agency that runs the Anchor ED program and are peers in recovery.; - ED reaches out to Anchor when a peer is needed in the ED.; - Responsible for meeting patients in the ED within 30 minutes of ED’s call.; - Try to build understanding and share lived experiences with patient.; - Discuss patient’s treatment options; link patients to the option they choose.; - Link patient with a navigator for follow-up if desired.

Relationship with Community Programs. To connect patients with ongoing care, EDs facilitate warm-handoffs to specialized treatment providers, including hospital-based bridge clinics and community-based outpatient providers. Across the five case studies, several approaches were used. In three of the cases, the ED connected patients with an outpatient program that was part of the hospital system (Denver, Marshall) or closely affiliated with the hospital (Highland). The NY MATTERS program focuses on developing relationships with community-based organizations and connecting patients from EDs across the state with these community-based providers. The Anchor ED program is a community-based substance use treatment organization.

- In the DHHA program, a large and integrated health system, the ED connects patients with the outpatient treatment and medical services as needed available through the DHHA outpatient behavioral health department.
- The Marshall ED maintains connections with several community health centers that provide outpatient treatment and the Marshall CARES clinic, an outpatient clinic that is right around the corner from the hospital, which helps mitigate transportation challenges. The CARES clinic is affiliated with the hospital and run by the behavioral health department. Marshall staff reported that being in a rural community where everyone knows each other helped to facilitate communication and relationships among organizations.
- Highland Hospital patients who start medication treatment in the ED are connected with a low-barrier bridge clinic on the grounds of the hospital. The bridge clinic is not part of the Alameda Health System but is funded by state grants and works closely with the ED, including employing some of the ED staff.
- NY MATTERS develops and maintains relationships with community-based outpatient treatment providers and maintains a database of more than 250 available appointments weekly. Patients select a convenient program from the database and receive a referral for ongoing treatment.
- The Anchor ED program is a community-based program that connects patients in the ED with peer recovery specialists and stays in touch with patients following the ED visit. If patients are interested in MOUD and/or outpatient treatment, the peers and the Anchor program will help connect patients appropriately.

In addition to building relationships with outpatient treatment programs, interviewees from some case study sites describe partnerships with other community-based organizations. The NY MATTERS program partners with Walgreens and Wegmans to offer vouchers that cover patients’ copayments for buprenorphine prescriptions. The program is also working on a partnership with Uber to help patients who need transportation to appointments.

“A woman who was 7 months pregnant called the [county] line and [was] immediately directed to Highland ED… I talked to her and figured out a plan for her to be admitted to the hospital 20 minutes later.”

– ED physician

Some programs also conduct outreach to the community to share information about the availability of treatment for OUD. ED leadership from Highland Hospital actively reach out to community-based providers, “So we have partnerships with the county jail…the detox center…with the other clinics that are treating patients with substance use disorders, the Pain Clinic…[and the] Harm Reduction Coalition and then various community partners.” The mayor of Denver ran a public relations campaign that “drove demand” to the DHHA program. Anchor ED is run by a community treatment program and is very much involved in state policy development and widespread education of health care organizations in the state.

The combination of structure and the relationship between the ED program and the outpatient program is key to supporting both patients and providers. Clinical experts reported having a reliable outpatient program was critical to making physicians willing to offer buprenorphine induction in the ED. When clinicians knew they had a reliable referral network, and additional follow-up from the ED physicians or staff would not be required, they were more willing to start a patient on medication treatment.

Financing. Cases use a combination of health insurance reimbursement, state block grant funds, and private and federal grant funding to pay for ED-based programs. In most cases, initial and continued funding of ED OUD programs is through grants such as the SAMHSA STR/SOR grants. In the case of the DHHA program, funding is provided by a combination of sources, including the Denver Mayor’s office. NY MATTERS program received private foundation funding. While many programs remain grant-funded, several have integrated programs into hospital or health system budgets.

Financing some aspects of ED-based OUD treatment programs is a particular concern for programs. According to interviews, billing for work by non-clinical providers, such as navigators, is not always allowed by insurance companies. Therefore, grants are often used to pay for navigators. One ED physician reported, “the least expensive staff are the hardest to pay for.” One interviewee argued that if insurance companies paid a bundled rate for substance use services, this might be a good way to cover the expenses the ED incurs when treating patients, providing MOUD, and employing navigators.

The community-based program, Anchor ED, relies on block grant funding from the state and reports this is a concern. One Anchor ED interviewee commented that if hospitals could employ peers directly, it would help with sustainability.

“A big thing for us was to have the Medical Center recognize that this was important and sustain the clinic and the [navigators] with hard funding.”

– ED physician

Finally, interviewees reported concern about low reimbursement rates for behavioral health services overall and reported that reimbursement rates do not always cover costs. One DHHA interviewee expressed frustration that reimbursement rates are higher for primary diagnosis of depression than for SUD and argued that, “If we don’t have parity of reimbursement, we aren’t going to have treatment.”

## Plans for continued implementation and sustainability

As noted, most programs started with initial seed funding from grants but have become an integral part of the ED. One expert explained once these programs are implemented and administrators see the impact, it is hard to eliminate them. One hospital reported that having the hospital system buy-in to the navigator approach has helped with financing and sustainability. An interviewee at Marshall Hospital reported that although it is difficult to finance some aspects of the program, “It will be extremely difficult to extract [the program] from our department. We can still continue services even if there isn’t specifically designated grant funding for it.” For programs that remain grant-funded, however, it continues to be a burden to programs to seek funding through ongoing cycles and is a risk to program sustainability.

Several hospitals are working on expanding their programs, in part as a way to improve sustainability. Most programs had plans to expand to treat substances beyond opioids in order to meet patients’ changing needs and to more efficiently use resources like navigators. One program plans to implement a patient registry, develop a training academy for providers, and improve system-wide approaches to bill for navigators.

## Expansion of ED OUD programs to other substances, including stimulants and alcohol

Interviewees repeatedly noted that due to the success of the ED OUD programs, they have expanded or plan to expand their focus to address other SUDs. In particular, identification and treatment of alcohol use and stimulant use disorders was a target for emerging programs. Programs emphasized that a low-barrier approach to OUD treatment includes providing treatment to those using multiple substances. Program representatives acknowledge the additional challenges that the use of these substances present: treatment is not as clearly medication-based or safe and effective as OUD medication treatment. However, expanding to other substance use was discussed near-universally among ED OUD programs studied as an important next step. As well, it was noted that expansion of the program was facilitated by the OUD program’s pioneering work in reducing stigma, increasing knowledge about SUD and the populations affected by it, and creating a culture of self-efficacy among providers.

## How programs are using metrics to assess their performance

Efforts to examine the effectiveness of ED-based OUD programs in the literature include a variety of patient-level process and outcome measures, as well as system-level measures of the structure of the health care system (Appendix 1). Process measures are most commonly used, primarily patient engagement with ongoing treatment at various time points following initiation of medication in the ED. Validated quality measures have been developed by the National Qualify Forum and National Committee for Quality Assurance related to OUD identification and treatment.^84^ However, the studies we identified generally do not describe the use of these nationally validated measures but rather self-developed measures. Outcome measures are more difficult to track because contact generally is limited to the patients with whom the program is able to follow up.

All programs included as case studies have their own reporting procedures for internal program monitoring or for reporting to funding agencies. The detail and scope of measurement varies, although all track linkage to treatment and engagement in treatment at various time points. For example, the Anchor ED program generates quarterly reports for the state that include a range of patient demographics, substances used in addition to opioids, contact and response times for recovery specialists to see patients, and engagement. A range of analytics are produced by DHHA because the hub (the behavioral health department) and most of the spokes are contained within the DHHA. They track the throughput of patients through the entire system (e.g., not just if there was a linkage, but the part of the system where each linkage happens). A few of the cases are large enough to have dedicated staff focused on data and analytics. In addition to tracking overdoses and ED utilization, NY MATTERS collaborates with the state to use state syndromic data on overdoses to assess programmatic success and as an indicator for expansion to new hospitals.

Metrics used by programs for assessing effectiveness of ED-based intervention for OUD

- Literature focuses on process measures including initiation rates and outpatient treatment engagement rates.
- Measures are frequently obtained through patient self-report of engagement and drug use.
- Programs have a range of metrics to report activity and impact, mostly process.
- Current measures do not generally assess life experiences.

Measuring the impact of programs on patients’ lives and relationships was identified as important by several interviewees. However, programs do not systematically measure patient-centered outcomes, in part because of measurement challenges. One physician mentioned the difficulty of measuring the work of non-clinical staff and challenges in measuring patient-centered outcomes. Indeed, patient-centered outcomes were generally anecdotal. For example, one recovery specialist mentioned feeling motivated when they are “able to see the incredible progress of individuals that sustain recovery and change their lives.” An ED nurse referred to patients “being able to get their quality of life back,” while an ED doctor said, “if patients show up again, we presume they like the service.” One exception was at Marshall, where the program resulted in changed obstetrics department policy, and they actively tracked the percent of mother-baby dyads kept together among mothers who gave birth to a baby with neonatal abstinence syndrome.

## Impact of the COVID-19 pandemic

Changes during COVID-19 altered some activities but also led to additional insights. For instance, it was clear that in spite of the additional burdens place on EDs by the pandemic, the programs studied remained in effect and continued to identify and treat patients. Programs quickly pivoted to adjust to the pandemic by working remotely with patients for treatment and follow-up. This suggests that the ED OUD programs are very much an important part of the work of EDs, particularly since COVID-19 has been accompanied by an increase in opioid overdoses.

## Barriers and facilitators to ED-based OUD efforts

Barriers to offering OUD treatment in EDs include stigma, lack of social supports, availability of treatment follow-up, and funding. These all contribute to the lack of availability of outpatient treatment services and create challenges. Interviewees also identified several facilitators to implementing ED-based OUD treatment and identified approaches to overcome some of the barriers identified. These approaches include being patient-centered, lowering barriers to treatment, having a champion and a knowledgeable expert in the ED, building relationships with community partners to support continuity of care, facilitating communication between ED and outpatient programs, offering provider OUD education, and funding.

### Barriers to success

#### Stigma associated with opioid use disorder and patients with OUD

Stigma towards patients with OUD and toward MOUD remain pervasive problems even in the most successful programs, both among providers and in the community. Stigma among ED providers may result in their being unwilling to seek training to prescribe buprenorphine, leading to less availability of MOUD. It also may lead to staff making patients feel less welcome in the ED.^85^ In the community, stigma related to MOUD can be an important factor limiting provider referrals to MOUD and reducing acceptance of MOUD by patients. Stigma against people with OUD also results in decreased community support for programs, both in the ED and elsewhere.^86^

Stigma results from, and also contributes to, lack of education about OUD treatment in medical and nursing schools, thus preventing ED staff from knowing how to treat OUD and understanding the potential for successful treatment.^87^ One ED physician described stigma as an outgrowth of a lack of awareness of effective treatment: “A ‘those patients’ attitude is likely because they don’t have a solution and don’t want to feel bad at their job.”

#### Limited capacity and availability of reliable outpatient treatment and needed social supports

“There needs to be a space for protecting ED providers because the cases are so complicated, chaotic, and confused. The histories are sometimes incorrect, and patients may have concurrent or undocumented prescriptions.”

– ED physician

EDs need a reliable outpatient treatment program where patients can go for follow-up and ongoing treatment. Sites have a range of models for outpatient care; the key is that the referrals be reliable so that ED providers can count on their patients connecting with care. One interviewee explained the key to implementing their program was telling ED providers, “All you have to do is provide buprenorphine; we will protect you and take care of everything after that; you can never make a wrong move.” However, high-quality, reliable outpatient treatment is not always available.

All sites described outpatient treatment capacity and availability as a barrier to starting treatment in the ED. One site reported difficulties connecting patients with outpatient care resulted in sending patients to less appropriate levels of care, “There are capacity issues in terms of seeing everyone in the ED and then finding a next day place to send the patients. The result is that the team is not always linking patients to the right level of care.” Another site reported a lack of capacity for higher levels of care.

Similarly, another interviewee described the challenges with trying to find outpatient treatment for patients, “ED folks are overwhelmed. They are constantly asked to do research for this or linkages to that. They are saying, ‘I am just trying to keep this person alive.’ That is where the champion comes in to help push and streamline the process.” Many interviewees maintained that finding treatment also involved securing housing and other supports for some patients.

To build this capacity, interviewees set up relationships and educated themselves on resources available in the community to help support patients. Collaboration with outpatient treatment programs is critical; interviewees reported having good transition processes and good working relationships between ED and outpatient care is important to success.

#### A lack of information and knowledge about OUD treatment

Lack of training and education among doctors, nurses, and other providers regarding SUDs in general, and OUD in particular, was identified as a barrier by all sites. Several sites reported physicians, nurses, and other staff were initially skeptical of medication treatment for OUD. A hospital administrator explained significant education and culture change were needed. They reported staff were initially skeptical of medication treatment and asked, “Is this a problem that needs this kind of intervention?” At one site that has been offering medication treatment for several years, some providers continue to not provide treatment, but enough have started that someone is generally available 24x7 in the ED. One interviewee reported that providers have different levels of comfort with buprenorphine which led to variability in use. An interviewee at another site said providers did not know much about buprenorphine and were afraid of doing harm, for example, by putting a patient into withdrawal, and this led to hesitancy to offer buprenorphine.

“Nurses are very much involved now. There are signs out in the lobby, patients will sometime request help from a triage nurse. Nurses support the program from the very first interaction. ‘It really takes a team to treat any disease process.’”

– ED nurse

Three sites described the importance of educating nurses and receiving their support in order to have a successful program. An ED charge nurse reported providing “Extensive on-shift education and outreach with the nurses” on her team. This nurse said it took time to build awareness of the program among nurses and get them on board. An interviewee at another site explained, “Getting nurses to see the importance of the program was critical because nurses spend the most time with patients.” Through education and culture change, sites were able to achieve nursing support.

#### Concern about ED workflow

Interviewees at two case study sites reported hospital administrators and providers expressed concern about how initiating patients on buprenorphine would affect ED flow. Patients have to wait to be in withdrawal before starting buprenorphine, and this can be a barrier if space is limited. However, programs that offer home induction are able to move patients through more quickly. In addition, seeing the impact of starting medication treatment has helped providers be creative and more accepting of sharing space with persons receiving treatment. NY MATTERS reported that when they receive pushback and concern about how this will interfere with ED flow, they respond by “Proving to hospitals that this will not interfere and will actually improve outcomes.”

#### Coordination with outside organizations

All programs depend on relationships with the organizations that will provide ongoing treatment. For hospital-based programs, this involves establishing relationships with community partners. These arrangements are developed through the hard work of ED program staff or hospital leadership. The Anchor ED program is run by a community-based organization and provides on-call recovery support services to hospitals throughout the state. Some Anchor ED interviewees described the challenges of effectively collaborating between a community-based organization and EDs. Interviewees reported difficulties for recovery specialists with criminal records, for instance, to be approved to work in EDs. Another interviewee reported challenges with “introducing outsiders into an emergency response team”; however, they felt that once the program was known, it was welcomed. Two interviewees explained, “there is not a clear process for hospitals to reach out to the community-based organization with concerns or challenges.” The frequent turnover among ED staff means that Anchor ED staff have to “market the program constantly.”

Another challenge in working across organizations is data sharing. It is difficult for hospitals to track engagement with community partners because of data and privacy restrictions. Data systems are not linked, and privacy laws prevent seeing where people are engaged in treatment at different times.

#### Lack of insurance, cumbersome intake policies, and medication costs

Three sites described lack of insurance, insurance company policies, and high cost of medication even with insurance as barriers. One interviewee reported that lack of insurance “stops a lot of people from seeking care. Paying out-of-pocket is not always possible for patients.” An interviewee from NY MATTERS explained that out-of-pocket costs for medication can be a barrier to treatment and described their voucher system with Walgreens and Wegmans as a potential solution. Walgreens and Wegmans accept vouchers NY MATTERS gives patients so that patients can receive medication at no cost. The vouchers are then billed back to the NY MATTERS program, which uses state STR/SOR funding to pay for the medications. Prior authorization requirements for buprenorphine were mentioned as a barrier that requires ED staff time to address. Another interviewee described the counseling intake process with required medical necessity and psychosocial screening as onerous and difficult for someone using substances or in withdrawal to complete.

#### Funding

Three sites described funding as a significant barrier. Specifically, sites that use navigators expressed difficulty paying for these staff when they are not able to bill insurance for navigators’ activities. One interviewee explained, “The hardest thing is to pay for the peer recovery coaches/navigators even though they are the lowest-paid people in the hospital because it is not clear how to bill for them. However, they are a key to all of this as they are extremely helpful with reducing stigma for patients.” Interviewees reported that financing mechanisms with more flexibility (e.g., bundled payments) to cover the cost of navigators were uncommon.

#### Buprenorphine X-Waiver requirements

While obtaining an X-Waiver may reduce the training and education barrier, the time commitment and investment required for the X-Waiver was described as a barrier by most sites. One site reported individuals have expressed interest in completing waiver training but have not taken the time to do it.

### Facilitators of success

#### Patient-centered, low-barrier approach promotes uptake of treatment

Several interviews across all case study sites emphasized the importance of taking a patient-centered approach to OUD treatment. Lowering barriers by making treatment available in a respectful, non-stigmatizing way and without delay has been recognized as an important facilitator to initiation and engagement in OUD treatment.^57,85,88^ Lowering barriers to care in the ED is accomplished through approaches such as having navigators available in a timely manner to interact with patients, facilitating follow-up with next day appointments, transportation, and warm-handoffs, treating people with SUD with respect, and letting patients make their own decisions. Lowering barriers to care was mentioned by all programs as critical for success in initiating and engaging patients in treatment.

Two sites reported community-based treatment programs’ policies, such as requiring that patients on buprenorphine not be using other substances and requiring negative urine drug screening tests, can be barriers to establishing partnerships and maintaining people in treatment. Interviewees described the importance of lowering the bar to start treatment by accepting any patient who wants MOUD. In order to do this, the NY MATTERS program established a “Mission, Vision, and Values Statement” that all community partners are required to sign to be included in their database. This statement requires community providers to meet specific requirements (e.g., be available for next day appointments, not exclude people from treatment if they are using other substances).

The interviewees at all sites addressed the importance of “Going to the bedside and talking to patients and treating patients as humans.” Several sites described the importance of “Engaging patients at whatever level they want to engage in” and “Meeting people where they are and getting them into treatment at whatever level the patient wants: medication treatment only is fine, medication and counseling is fine, counseling only is also available.” Another interviewee said their program, “takes patients with few rules and restrictions/requirements, and then transfers them to [ongoing outpatient] care only if that is what they want; they can also choose primary care or be kept within the program.” A navigator described helping a patient who was using opioids and methamphetamine start buprenorphine. The patient was allowed to start treatment despite other drug use and, after a period of time, asked for help with the methamphetamine use. Interviewees universally endorsed the importance of treating patients with respect and putting them in control of their own treatment.

“Really blessed and lucky to have strong provider champion. Clinicians that way back wanted to do more; when suboxone became available they jumped on.”

– ED Provider

#### A passionate champion and expert in OUD treatment

Across the five case studies, all sites had champions who were passionate and motivated to bring ED-based OUD treatment to their site. These individuals are emergency medicine physicians and physician assistants working in the ED. All are knowledgeable about OUD treatment and buprenorphine, have earned the trust and respect of their colleagues and worked to educate others on the team about the importance of buprenorphine. Most of the champions started offering ED-based OUD treatment on their own and grew the program as colleagues saw the possibilities and began to understand how much it could help patients. Programs were able to expand beyond the ED to other departments when those departments (e.g., OB/GYN, pediatrics) had their own champions. Related to this is the support of the hospital or health system in providing resources and personnel for the program, helping secure funding, and providing the needed autonomy of providers to develop programs and allow them to evolve as needed.

#### Strong structure to facilitate communication across partners and seamless treatment

ED programs depend on having consistent and reliable access to outpatient care for the patients that they initiate in treatment. Shared understanding and strong communication embedded in the relationships between the hospital and community partners are key to ensuring ED providers will be willing to start medication treatment to facilitate the successful transition of patients and engagement in treatment. Program leadership and stakeholders reported that having direct lines to treatment beds and outpatient appointments in a timely manner furthered patient care and also engendered ED provider cooperation and trust in the program’s effectiveness.

Programs effectively established these relationships in different ways. The structure of the DHHA program, the hub-and-spoke model with a management hub, facilitates regular and effective communication across settings. This is also likely made easier by the fact that most of the providers are situated within the DHHA system. The Highland program sends patients to a bridge clinic located just outside the hospital and staffed with some Highland ED physicians. Navigators at Highland work in both the bridge clinic and ED. NY MATTERS emphasized the importance of establishing relationships with organizations rather than individual people so that as people move to different jobs, the relationships are sustained and required outpatient programs to sign on to their “Mission, Vision, Values Statement” to establish a shared understanding between organizations. Other programs also effectively communicated across partners in different ways but sometimes had to rely on individual relationships or one component of the partnership driving communication.

#### Tracking performance

Systematically tracking treatment process and outcome data is crucial. Case study informants and subject matter experts reported that monitoring ED performance and feeding that information back to clinicians with stories of success is helpful for motivating providers. For example, one expert said they track the number of patients who have buprenorphine administered in the ED and, of these, the number that also received a buprenorphine prescription, to inform efforts to increase this rate. Experts also described having a repetitive process by which they monitor what happens with referrals and let ED physicians and nurses know. Sharing feedback and success stories about people who successfully engage with outpatient treatment with the ED providers can generate excitement and motivation for this work. Without this feedback, ED providers only see the patients who do not do well. One subject matter expert explained that tracking and sharing data with hospital administrators and with the community has facilitated goodwill for the program and can make obtaining necessary funding from the hospital easier.

iii A low-barrier approach to treatment in this context may be defined as having the following qualities: (1) Same-day treatment entry; (2) Harm reduction; (3) Flexibility; and (4) Wide availability in places where people with OUD can be treated.^57^

iv A peer navigator is a person who brings the lived experience of substance use recovery, combined with training and supervision, to assist others in initiating and maintaining recovery and helping to enhance the quality of personal and family life in long-term recovery.^69^ Peer navigators may also be referred to as peer recovery coaches or peer specialists.

v Recovery navigators are non-clinical staff who support individuals in their recovery by providing care management and helping patients navigate the health care and social service systems to support treatment engagement and recovery. They may also be called recovery coaches or recovery specialists. In this report, the term “peer navigator” refers to someone with lived experience of substance use recovery while the term “recovery navigator” is more general and refers to individuals who may or may not be in recovery themselves.

vi The hub-and-spoke model is a system of care in which a hub (i.e., ED, specialty SUD treatment program, etc.) acts as a centralized referral source, connecting patients to a network of providers who provide care to individuals with chronic conditions (i.e., OUD).^82^