# Methods

Information for this report comes from three sources: an environmental scan^58^ comprised of a literature search and interviews with subject matter experts and case studies of five ED OUD programs.

## Environmental scan

A literature search was conducted, including peer-reviewed literature, government reports, and white papers. PubMed and Google Scholar were searched for 2015-2020 to identify articles related to the implementation and effectiveness of ED-based OUD treatment and to identify potential experts to interview. Searches used the following keywords: opioid use disorder, buprenorphine, Suboxone, medication-assisted treatment, MOUD, and ED. Reference lists in identified sources were examined to “snowball” additional sources, including those published before 2015. We identified papers that analyzed efforts to change practice, described implementation, and described barriers and facilitators to ED-based OUD treatment.

Potential subject matter experts were identified first by scanning recent conference proceedings and highly cited articles in the literature. Through initial expert interviews, additional informants were identified. Semi-structured interviews were conducted between November 2019 and January 2020 with eight emergency medicine and addiction medicine physicians and researchers who have developed or are key leaders within ED-based OUD programs. Experts were based in academic and community health centers, EDs, and addiction medicine bridge clinics,^ii^ and all were part of programs that offered medication treatment for OUD. Via telephone conversations with the authors, respondents were asked to provide an overview of how their ED-based OUD treatment program worked; identify key components of the program; and identify barriers and facilitators to implementation, operation, and sustainability. The interviews were analyzed for major themes and insights using an inductive approach. Aspects of program design and key components were identified by applying a framework analysis approach to the literature and interviews.^59^ Initial findings from the literature search and subject matter expert interviews are summarized in an environmental scan and manuscript.^56,60^

## Case studies

Following the literature search, expert interviews, and environmental scan, five case studies of ED programs for OUD were conducted. Cases were selected to represent the range of structures among program sites (e.g., health system-based, state-based, individual ED). Data collection and analysis were designed to generate actionable information for model replication. Standard methods for case studies were used, adapted from those developed by Yin, which guides data collection, analysis, and reporting.^61^

Site Selection Criteria. Based on the environmental scan and interviews with experts, we established criteria for site selection. We proposed to interview programs that vary in stages of maturity and those that represent a range of key components, including type of intervention, location, size, and structure (statewide vs. individual ED). To facilitate selecting program sites, the authors developed a matrix of key components of programs.

Interview Instrument. The interview instrument consisted of the domains addressed in the research questions and was informed by the literature search, expert interviews, and our knowledge of the unique factors and barriers to initiating and continuing OUD pharmacotherapy (see Appendix 3). The instrument included major topics and probes to address them in more detail. Major topics included: key components of the programs; background on the development and motivation for starting the program; linkages with other providers or services and how they have been developed and nurtured; any program evaluations that have been conducted; funding and sustainability plans; and barriers and facilitators experienced.

Recruitment of Study Sites. Several nationally recognized leaders of ED-based OUD programs were enlisted as advisors to help facilitate recruitment through contacts with programs and national organizations such as the American College of Emergency Physicians. To recruit sites, an author emailed the program director, summarizing the project and why their program may be an important model to include. Each site was offered an honorarium of $2,000 for their time.

Participating sites. Ten potential case study sites were initially identified. Sites were reviewed with ASPE and selected based on established criteria: range of models, maturity, size, urban/rural area, location. Five sites were selected; one declined and was replaced. Participating sites are identified in Table 1.

Table 1 Case Study Sites

Program | Location | Description
Denver Health and Hospital Authority (DHHA) | Denver, CO | Hub-and-spoke model; includes a range of disciplines
Marshall Medical Center | Placerville, CA | Rural program noted by experts as successful; community hospital
Highland Hospital, Alameda Health System | Oakland, CA | One of the largest programs, very successful. Most experts referred to this program
NY MATTERS | New York | Statewide program, operates in 17+ EDs; initially foundation-funded
Anchor ED | Rhode Island | Statewide effort, community provider based

Conducting Case Studies and Data Collection. All site visits, consisting of interviews and document review, were conducted remotely due to COVID-19. Site leadership identified key persons for interviews, which were supplemented as needed to provide a complete picture of the program. Semi-structured interviews were conducted with ED providers, program developers, program staff, and other key stakeholders, including state representatives as relevant. Interviews were recorded and transcribed, and detailed notes were taken. Interviews took 45-60 minutes and were conducted with up to nine staff and stakeholders per site. Secondary data, including reports and internal documents, were requested from all sites. Site summaries were prepared and shared with programs for validation (Appendix 2).

Data Analysis. A framework analysis approach was used to code, summarize, synthesize, and sort qualitative data collected for analysis. Themes were identified initially based on the environmental scan and research questions; additional themes were identified inductively through analysis of the interviews. Interview findings were analyzed by theme and summarized by research question.

i Pennsylvania defines a warm-handoff as a seamless transition for patients from emergency medical care to specialty SUD treatment.^52^ Warm-handoffs can be to any OUD treatment provider including primary care.

ii Bridge clinics are easily accessible buprenorphine clinics that aim to remove barriers for induction into buprenorphine treatment and help connect patients to long-term OUD care.^57,58^