# Introduction

The United States is facing a crisis of opioid overdose deaths. More than 70,000 people died from a drug overdose in 2019, and approximately 49,000, or 70.6 percent of those deaths involved opioids.^1^ If current trends persist, 2020 drug overdose deaths may exceed 90,000 people,^2^ the highest number ever recorded in the United States.^3^

For many individuals with OUD, initial contact with the health system occurs in the ED while experiencing an overdose or withdrawal symptoms. Mortality after ED visits for opioid overdose is high.^9^ A study of patients in Massachusetts EDs found 5 percent who survived an opioid overdose died within one year of ED discharge. Among this group who died within a year, 20 percent died within one month of the ED visit, and 5 percent died within two days of leaving the ED.^4^ When patients are experiencing withdrawal, they may express interest in treatment, and it is essential to provide treatment at that moment before patients go back to using opioids.^10^ Thus, EDs are an important place to intervene to prevent death and a “critical entry point” for individuals with OUD to potentially access treatment.^11^

EDs are increasingly addressing OUD with medication or initial contact with treatment providers, including supports to connect with outpatient treatment. This report examines how ED-based programs to treat OUD are structured and financed and identifies lessons from established programs’ experience.

The objective of this report is to address the following research questions, followed by implications for policy and practice:

1) What ED-based interventions exist to initiate OUD treatment?
2) What is the evidence base for ED-based interventions to initiate OUD treatment?
3) What factors motivated the development of ED-based interventions for OUD?
4) What are the key components of ED-based models to treat OUD?
5) What are the plans for continued implementation and sustainability of ED-based interventions for OUD?
6) How are programs assessing the effectiveness of the ED-based intervention for OUD?
7) What barriers and facilitators have programs encountered, and how have they addressed the barriers?

## Background: Treatment for opioid use disorder

Most people with OUD go untreated with severe health and public health consequences.^11,12^ Access to OUD treatment has improved, with medications now available from specialty addiction treatment settings and primary care and office-based prescribers. However, 80 percent of individuals with OUD do not receive treatment.^13,14^ A recent study showed 95 percent of Medicaid enrollees with OUD under the age of 18, and 73 percent of those ages 18-21 did not receive timely medication treatment for OUD.^15^ Provision of OUD pharmacotherapy is also low among the commercially insured, with only up to 25 percent of commercially insured individuals with OUD receiving medications.^16^ There are many barriers to receiving OUD treatment, including provider availability, stigma, and insurance coverage policies.^16–20^

Reasons for low rates of OUD treatment are varied. According to the National Survey on Drug Use and Health, 95 percent of people with SUDs who did not receive treatment in the past year do not think they need treatment.^20^ Among those who perceived a need for treatment but did not receive treatment, reasons include not being ready to stop using, not knowing where to go for treatment, not having health insurance or being able to afford treatment.^20^ Among those who seek treatment, provider availability, stigma, and health plan policies can be barriers to access.^16–19^

Medication is an effective, evidence-based practice for treating OUD.^21–24^ While it is important to consider medication in the context of psychosocial supports, experts acknowledge that medication is still preferable in the absence of available counseling.^6^ There are three approved MOUD:

- Methadone, an opioid agonist that mitigates cravings and withdrawal symptoms.
- Buprenorphine, a partial opioid agonist that mitigates cravings and withdrawal symptoms.
- Naltrexone, an opioid antagonist that prevents euphoria. Patients must be off opioids before initiating treatment with naltrexone to avoid precipitated withdrawal.

The three OUD medications are effective and cost-effective in reducing opioid misuse.^25–27,7,28–30,22,5^ Clinical practice guidelines and treatment recommendations encourage pharmacotherapy as a front-line treatment.^27,31–33^ Pharmacotherapy for OUD results in reduced opioid use, longer time in treatment, fewer relapses and overdoses, and lower mortality.^7,23,28,29,34,35^ Societal benefits include cost reductions related to criminal activity and health care utilization. However, only 36 percent of outpatient substance use treatment programs offer pharmacotherapy for OUD.^14^

## OUD medication treatment regulations

Methadone was HHS Food and Drug Administration (FDA) approved for OUD in 1972 and was the only medication available to treat OUD until the FDA approved buprenorphine in 2002.^25^ Restrictions on methadone remain considerable and include dispensing solely through approved opioid treatment programs (OTPs), subject to state and federal regulations. The Drug Addiction Treatment Act (DATA) of 2000 enabled qualified physicians to obtain a waiver (frequently called an “X-Waiver”) from the Controlled Substances Act allowing them to prescribe buprenorphine-containing medications approved for the treatment of OUD (referred to as office-based opioid treatment, or OBOT) to up to 30 patients.^36^ The Office of National Drug Control Policy Reauthorization Act of 2006 increased patient limits from 30 to 100 patients at a time;^37^ the limit later increased to 275 patients.^38^ In response to requests to further raise or eliminate the patient limit, the Comprehensive Addiction and Recovery Act temporarily authorized nurse practitioners and physician assistants to prescribe buprenorphine for OUD for up to 30 patients and up to 100 patients after one year.^39^ The SUPPORT for Patients and Communities Act permanently extended this authorization for nurse practitioners and physician assistants and authorized other advanced practice registered nurses (Certified Nurse Midwives, Clinical Nurse Specialists, and Certified Registered Nurse Anesthetists) for a limited amount of time.^40^ In April 2021, X-Waiver requirements were relaxed to eliminate the required eight hour training and availability of counseling and other ancillary services for administering buprenorphine to 30 or fewer patients at a time.^41^ Still, insufficient OBOT capacity persists, particularly in rural areas.^42–44^

Buprenorphine prescribing regulations include an exception to the waiver requirement for an emergency setting, called the “three-day rule.” This exception allows a non-waivered clinician to administer (not prescribe) narcotics to “treat acute withdrawal symptoms while arranging for the patient’s referral for treatment under the following conditions: not more than one day’s medication may be administered or given to a patient at one time, treatment may not continue for more than 72 hours, and the 72 hours cannot be renewed or extended.”^45^ Scientific evidence regarding the merits of MOUD is clear. However, access to MOUD is limited due to insufficient capacity, inadequate reimbursement, long waiting lists in many communities, lack of institutional support, inadequate patient and provider knowledge regarding OUD medications, and stigma of multiple types.^24,46^

## Federal and state efforts to expand OUD treatment access

Federal and state agencies have launched initiatives to address the epidemic and enhance access to treatment in response to the increasing rate of opioid-related deaths. Federal efforts directed more than $7.6 billion toward the issue in 2019.^47^ The Federal Government has dedicated funding to states to develop and implement programs specific to OUD prevention, treatment, and recovery. Expanding access to OUD treatment was a requirement of the STR grant in 2017 to “design, implement, enhance, and evaluate primary and secondary prevention using evidence-based methods proven to reduce the number of persons with OUDs and OUD associated deaths.”^48,49^ Some states used STR funds or the subsequent SOR grant for ED-based efforts to address OUD.^47^

At the state level, both funding and regulations have been implemented. Although no systematic documentation of programs for all states is available, both Massachusetts and Pennsylvania are examples of states devoting resources to ED-based OUD programs. In Massachusetts, over $6 million was invested in nine hospital and health systems to design and implement ED-based OUD programs focused on identifying patients, initiating treatment in the ED, and linking to community services.^50^ The state has also passed a law requiring that acute care hospitals with EDs have the capacity to start patients on MOUD when they present in the ED after an opioid-related overdose. The Massachusetts Hospital Association published guidelines for all hospitals to implement such programs.^51^ In Pennsylvania, the state implemented a Hospital Quality Improvement Program for OUD in 2019.^52^ The first-year goal was to improve ED-based treatment of OUD.^53^ This initiative offered Pennsylvania hospitals financial incentives to develop one or more of the following treatment pathways for people with OUD: ED-based initiation of buprenorphine with a warm-handoff^i^ to a community provider, direct warm-handoff to a community-based provider for OUD treatment (medication or abstinence-based), a specialized protocol for pregnant women with OUD, an inpatient admission pathway for methadone and observation for buprenorphine induction.^56^ The state is also promoting efforts to connect overdose survivors with OUD treatment by requiring all single county authorities to establish warm-handoff policies.^57^