# Appendix 3 Interview guide

## Emergency Department Interventions for Opioid Use Disorder

### A About you and your program

A1 What is your role at (insert program)?
  - How long have you been at (program)? In this particular role?
  - What aspects of this project are you or your (program) responsible for?
  - Were you involved with the development of this program? In what capacity were you involved?
  - How much of your time is dedicated to this program?
A2 Please tell us more detail about the program history and structure. [probes]
  - How long has it been in place?
  - What was the original vision and how did it develop?
  - What department is it run out of (e.g., ED, behavioral health, etc.)?
  - Is there a bridge clinic on site or nearby?
  - How was it funded? Ongoing funding?
  - What is the size of the program -- how is it staffed, patients evaluated per day/week, patients treated?
  - What has changed during the COVID-19 epidemic?
A3 Features of the program. Please describe the following:
  - Population served.
  - Patient identification in ED.
  - Mode of medication initiation.
  - Structure and maturity.
  - Care coordination model.
  - Integration with community treatment programs.
  - Other community partners involved.
  - Health system structure/unit of organization.
  - Motivation for starting the program.
  - Financing, sustainability, evaluation.

### B Program Success

- How are you monitoring activity and measuring success?
  ○ In which ways do you assess effectiveness, and which metrics have been used (e.g., numbers initiated, change in ED visits, engagement in treatment)?
  ○ Are you using surveys or qualitative interviews by which you assess effectiveness, including for staff and for patients?
  ○ What have been the outcomes of your assessments?
- What do you feel are the most important features in contributing to the success of ED programs to address OUD? (see above list)
- What are unique aspects of your program that you think particularly important and useful for policymakers to be aware of?

### C Barriers to success

- What are some barriers to success? [probes]
  ○ Financial/budget/insurance.
  ○ Time availability.
  ○ Clinical issues.
  ○ Recruiting clinicians.
  ○ Engaging community providers.
  ○ Stigma.
  ○ Data.
  ○ Administrative.
  ○ Technical.
- How have you addressed any of the barriers that you have mentioned?

### D Sustainability and future outlook

- How do you plan to sustain the program moving forward?
- What resources would be needed to sustain the work?
- What are key considerations or lessons learned for other EDs who are considering establishing an ED OUD program?

### E Additional

- What changes would you make to this program if you were designing it again?
- Is there anything else that you think is relevant to this discussion that you would like to add?