# Appendix 2 Individual case summaries

## Denver Health and Hospital Authority Case Study Summary

### Program snapshot

The Denver Health and Hospitals Authority’s (DHHA) medication for OUD program is part of a hub-and-spoke model of treatment. The Center for Addiction Medicine (CAM) at DHHA has its “hub” at the hospital’s Outpatient Behavioral Health Department, and the ED is a spoke. OUD treatment efforts in the ED are primarily facilitated by the TOD program. Most partners are located within the DHHA system, and coordination across the ED and other partners is managed by CAM, a feature built into the structure of the model. This high level of integration and coordination allows movement across settings (i.e., from ED induction to next day follow-up treatment) and often works seamlessly. The nascent program took advantage of a MAT-PDOA SAMHSA grant, followed by local and other funding sources, and has grown into a “no wrong door” approach serving over 1,000 patients per year. Activities are expanding beyond opioids to address other substance use, including alcohol use disorder and stimulant use disorder. Data for this case study was collected through interviews with individuals in the following roles:

- ED physicians.
- CAM outpatient behavioral services clinicians and staff.
- TOD program staff.
- Program data manager.

The team also reviewed the following documents shared by DHHA and partners:

- Reporting summary dashboard for the program (Tableau reports).
- Program website materials.
- Annual report.
- Assorted abstracts and manuscripts describing the project and related work associated with the CAM.

### Description of the program

#### History of the program

Between 2014-2017 as the OUD crisis escalated, the DHHA system could not adequately serve persons in need of OUD treatment. Providers knew that if someone could not get into a treatment program easily, their chances of coming back were low, and the dangers of fatal overdose increase over time. Patients had to wait about two weeks to access addiction treatment because there were few clinics. For methadone, patients had to present at 5 AM for intake, which made it challenging to access treatment.

#### Size and patient population

The program serves mostly residents of the greater Denver area. The patient population is largely White or Hispanic. Most patients have Medicaid. Patients are not turned away due to lack of insurance. Approximately 33-40 percent are chronically homeless, a number that has increased in last two years. Patients are more consistently reporting fentanyl use (estimated at 50 percent). About 30-40 percent of patients have no phone, creating a challenge for follow up.

#### Approach to patient identification

Demand for OUD treatment is generally patient-driven. The Mayor conducted a large public relations campaign early on, so community awareness of the services is high. Nurses will refer patients if they see an opportunity. If a patient with OUD touches the ED for any reason, the physician’s assistant or other staff will do a screening. Those who present to the ED with an overdose are typically not inducted at the time of the ED visit. The triage protocol is based on age and the Clinical Opiate Withdrawal Scale score.

#### Mode of initiating engagement with patients

Patients come in from many spokes; this is a “no wrong door” approach. Ideally, by the time the patient leaves the ED they have suboxone induction, an appointment for the next day with one of the follow-up treatment locations, and a naloxone kit.

The main places where patients are inducted are the ED and hospital. Due to COVID-19, remote inductions were started. Housing and transportation support services are also offered if needed at the time of induction, to facilitate follow-up engagement in treatment.

#### Program structure and key staff

Denver Health is a vertically integrated, safety-net system with a Level 1 trauma center, Federally Qualified Health Center (FQHC), family centers, school health centers, corrections, etc. Its MOUD program relies heavily on the professional staff both at the central component, the Behavioral Health department, and each of the spokes, particularly the pediatric and adult EDs. This structure provides a strong incentive to collaborate and coordinate across settings, from the initial entry of patients to immediate and long-term follow-up, and care of medical conditions as well. Community walk-ins are seen five days per week. The OBOT is close by and outpatient treatment programs are also available for daily dosing as needed. Before COVID-19, many patients would come to the outpatient program for daily dosing.

The role of recovery coach or navigator is filled by staff employed by the outpatient behavioral health services (CAM); none are specifically embedded in the ED. In the ED, there is a Screening, Brief Intervention, and Referral to Treatment (SBIRT) program. Nurses and physician assistants do initial alcohol and drug screening, and the two full-time SBIRT staff watch the ED board for alerts to go connect with patients. The SBIRT staff is available day and evenings, but not around the clock, to support the TOD team.

Outpatient treatment capacity has been expanded by moving lots of related treatment activity to the ED. Initial intake takes hours (induction, etc.), and patients have to get enrolled at the same time. The outpatient treatment program works as a bridge clinic for those that do not need a high level of care. For more intensive services, patients are admitted to the hospital.

#### Relationship with community partners

The MOUD program is becoming well integrated into and beyond the DHHA system. This includes: Psychiatric Emergency Services, methadone treatment, suboxone treatment, hospital medicine, correctional care, family health centers, Denver CARES and other community partners. However, the vast majority of patients stay within the DHHA system, which has a strong and wide infrastructure, including a university hospital. In addition, there is a direct referral protocol for patients with Hepatitis C, and direct referrals from a maternity clinic.

#### Financing and sustainability

Offering medication treatment for OUD in the ED was enabled initially with federal grant funding. However, it is now included in the DHHA budget and includes regular billing of Medicaid. Leadership feels there is need for a bigger team, though it is acknowledged that as the TOD team grows, there will be a need to increase capacity on the outpatient treatment side as well. Additional grant monies continue to be secured, for example, to assist patients who are uninsured. As an outgrowth of the TOD program, providers now have a pathway for treating patients with methamphetamine symptoms: they are identified in the ED, briefly admitted for symptom treatment and detoxification, and within 48-72 hours they are connected with a treatment provider including contingency management. This reduced ED revisits for these patients. The impetus for the methamphetamine protocol came from the police, who reported that many of their stops are now for methamphetamine related issues. The approach is now being expanded to alcohol use disorder. At present, the program is also considering a more centralized intake procedure for assessing where patients should be inducted, assessing insurance status, and special pathways for adolescents.

CAM is now discussing or engaging in several enhancements:

- Expanding the OUD continuum of care to alcohol use disorder and stimulant use disorder.
- Creating a system-wide registry to expand substance use assessment and then linking patients to the right level of care.
- Starting a Center of Addiction Training Academy and looking for training grants to teach, consult, and share knowledge with folks interested in doing this work.
- Expanding billing and financing system to maximize reimbursement for all SUD services provided.

Seeking additional aid for patients’ health-related social needs (e.g., more transitional housing and providing patients with phones to facilitate follow-up).

#### Metrics and measures of success

The CAM takes the lead in tracking patients and follow-up. Measures tracked include new treatment episodes, unique patients, number of days from ED to treatment follow-up, linkages to outpatient addiction services, retention in treatment at 60, 90, and 365 days.

For example, according to a recent report, of 891 system-wide inductions in 2020, 67.5 percent had follow-up with outpatient addiction services and 53.5 percent of those that were linked were retained in services at 90 days. The TOD program was responsible for 590 inductions, 69 percent of which were linked to outpatient services who then saw a 52 percent retention rate at 90 days.

### Facilitators and barriers to offering ED-based OUD treatment

Respondents identified several facilitators and features that contribute to program success:

- The highly coordinated structure of the program has allowed for greatly facilitated movement of patients and information across settings and throughout the continuum of care.
- Having a champion -- in each partner department -- is a major factor in success initially and now. Several ED providers have been “super champions,” demonstrating that prior to the program, there was nothing they could do for OUD patients, and now there is something they can do.
- Having SBIRT staff, social workers, or alcohol counselors on site/available. EDs are not designed to be the warmest place these staff can sit with these patients and be with them to listen to their stories.
- Nurse practitioners and physician assistants are available to do the majority of inductions.
- Financing strategy: The program aligned federal funding across different parts of the system. Also, the program pays providers to get the X-Waiver, especially helpful for residents, while educating them more broadly about SUD.
- Relationships were mentioned as a huge part of success. Process work is foundational, but relationships are really important. Need to be able to rely on colleagues. There is real collaboration with partners.
- The program has lowered the bar for treatment entry.

The following were mentioned as barriers:

- Treatment capacity issues: Even in an integrated program such as this, there are limitations in terms of seeing everyone in the ED and then finding a next day place to send the patients.
- ED staff capacity: Busy staff are constantly asked to do additional work to enhance care or linkages. Providers are not always available for bridge prescriptions. This is why next day appointments are required.
- Space capacity: Patients need a private space, sometimes for hours, if they are in withdrawal.
- Social determinants: The need in housing is great, but there are not any big initiatives to help out.
- Lack of skills and training to treat patients with SUD.
- Initially there was pushback from administrators who were worried about ED flow.
- Stigma.
- Data challenges: Referral partners are slow to provide follow-up data. TOD maintains an Access database which is outside of the EHR and is not always readily available to ED staff. HIPAA prevents easily seeing where people are engaged in treatment at times.

## Marshall Medical Center Case Study Summary

### Snapshot of the program

Marshall Medical Center is a free-standing, non-profit, Level 3 trauma hospital in El Dorado County, a rural area of California with approximately 185,000 residents. Paramedics have up to 45-60 minute transport times due to geographic barriers and rural areas to access.

The effort to initiate Marshall patients with OUD on buprenorphine and connect with care was started in 2017 by a physician assistant who had been working in the ED for more than 15 years. Initially it began with a protocol and an agreement with the community partner to provide anyone who started buprenorphine in the ED an appointment the following morning at 9 AM. The program has grown to include partnerships with other clinical sections of the hospital (e.g., obstetrics) and efforts to address other SUDs including stimulants and alcohol. As the program evolved, it became part of California’s Bridge to Treatment program, a statewide collaboration of hospitals implementing ED-based OUD programs.

### Information sources

Data for this case study was collected through interviews with individuals in the following roles:

- ED Physician Assistant (founder).
- Hospital administrator.
- ED physician.
- Obstetrics physician.
- ED nurse.
- SUD navigator.
- Community partner.

The team also reviewed the following documents shared by Marshall Medical Center:

- Program data and reports.
- Data from the obstetrics department describing referrals.

### Description of the program

#### History of the program

The program was started by a motivated ED provider without any funding. After the initial start, California Bridge funding was provided for navigator positions and to pay for X-Waiver training. Marshall assessed the highest threats to public health in the community, indices of SUDs and concluded SUDs were a major problem in El Dorado County. They started with a week-long session to identify the best approach and then identified high-risk patients. It was a community and Marshall collaboration.

Marshall was one of the first hospitals to sign up for California’s Bridge pilot at the same time the larger hub-and-spoke model was being deployed throughout the state. This resulted in Placerville, California as one of the few places in California where both models were used together (as of April 2019). The founding physician assistant found that treating people “quickly and effectively doubles the likelihood of them being in treatment in 30 days.” She followed up with early findings, “For the 49 weeks starting in August 2017, 92 percent of the patients treated at the hospital with Suboxone followed up by seeking care at a spoke, with the nearest one 15 miles away. After a year, 26 of those patients were still in treatment, accounting for a 74 percent success rate.” In December 2019, Marshall was named by the California Health and Human Services Agency to the Patient Safety Honor Roll. In 2018, El Dorado County recorded only seven opioid-related lethal overdoses.

#### Size

The Marshall Medical Center ED helped to initiate 38 patients on MOUD in the first year with a 74 percent retention rate. The program has seen a steady increase in buprenorphine administration and prescribing. In 2019, 119 patients received treatment with buprenorphine with 97 percent follow-up rate and 82 percent retention rate at one month. In 2020, 174 patients were treated with buprenorphine.

The program currently starts more than ten patients per month on MOUD and links them with community partners.

#### Approach to patient identification

About half of patients “self-refer” (i.e., come to the ED looking to start OUD treatment with medication [buprenorphine]). The program is advertised widely with signage in the ED, buttons that nurses wear, and on the hospital Facebook page. Case managers working with homeless individuals and local law enforcement are knowledgeable about the program and refer or bring patients to the ED.

Other patients start OUD medication treatment after coming in for an overdose or because they were on medication treatment and missed doses.

#### Mode of initiating engagement with patients

Patients start buprenorphine in the ED and are referred to one of several community partners for follow-up care the next day. The ED will also provide buprenorphine prescription if needed (e.g., after hours or on a weekend) and in cases where a patient may start treatment at home.

#### Program structure and key staff

After the initial stage, the founder assembled a team of ED providers of three physician assistants and one nurse practitioner who all completed X-Waiver training to enable buprenorphine prescribing.

Navigators were added after approximately 1.5 years.

Patients start buprenorphine in the ED and are referred to one of several community partners for follow-up care the next day. Referrals are sent to one of four community health centers with 9 AM next day appointments.

The ED is staffed 24/7/365 by providers familiar with treatment of OUD and a navigator is available in the ED and hospital Monday through Friday 10 AM-6 PM but also available by telephone to patients who are considering treatment or not yet established in treatment yet.

Other services provided include test strips for fentanyl and naloxone doses, with the message of, “The therapeutic door that you open with me will never close.”

#### Relationship with community partners

The program works with several community partners. Patients started on MOUD in the ED or hospital are connected with:

- The Marshall CARES Clinic, an outpatient SUD clinic affiliated with the hospital.
- Four community health centers including El Dorado Community Health Center, an FQHC.
- Residential program for pregnant women that supports MOUD.

Other organizations include pharmacies which facilitate medication treatment, law enforcement, case managers for homeless population, tribal heath center, and an information-sharing opioid community coalition.

#### Financing and sustainability

Initially the program was started without any additional funding. Today, the California Bridge to Treatment grant pays for one navigator and the hub-and-spoke grant pays for two (two in rural areas, one in ED) and also paid for providers to obtain X-Waiver training. Interviewees reported that sustainability will be a challenge when the grant ends.

The Marshall CARES (outpatient SUD treatment) program is funded in part through SOR federal funds directed to OUD treatment. This pays for staff, counselors and medical assistants. Sustaining this outpatient program may be difficult without the SOR funding because billing at current rate does not cover costs. California SOR funding also provides funds to cover medication copayments where needed, which enables patients without insurance to afford medications.

Considering its value, respondents report the program may continue beyond grant funding. One staff member notes, “It will be extremely difficult to extract [the program] from our department.” The program would still like to continue services in the ED even if there is not specifically designated grant funding for it. To that end, they are billing for everything they can, but the grants provide an important factor in the level of services right now.

#### Metrics and measures of success

A review of 2020 activity identified the following metrics:

- 195 patients seen with an OUD Diagnosis.
- 175 were provided with a buprenorphine Rx.
- 112 received referrals to treatment.
- 104 referrals were completed (the follow-up rate for referrals was 93 percent).
- 1 month retention in treatment was 81 percent.
- 74 percent of patients in treatment were new starts.
- More than half of patients seen in 2020 are still in treatment.

### Barriers and Facilitators to offering ED-based OUD treatment

Respondents identified several facilitators and features that contribute to program success:

- Champion with passion and drive.
- Patient-centered program.
- Low-barrier program (e.g., eliminating punitive aspects of treatment).
- Pharmacy partner that “provides mediation first and asks questions later”.
- Navigators’ attention to patients.
- Consistent and welcoming approach to treatment.
- Widely advertising the program through ED signage and buttons.

The following barriers were mentioned:

- Stigma (among both providers, patients, community).
- Lack of knowledge about OUD treatment options and their effectiveness.
- X-Waiver requirements.
- Availability of navigators during off hours.
- Lack of insurance coverage.
- Low reimbursement rates for SUD treatment.
- Copayments for MOUD.
- COVID-19 restrictions.
- Transportation difficulties for patients.

## Highland Hospital Case Study Summary

### Program Snapshot

Highland Hospital is a 236-bed acute care hospital located in Oakland, California and is the flagship hospital of Alameda Health System. Dr. Andrew Herring, ED physician, started offering buprenorphine treatment in the ED in 2017. Today, the program treats about 600 patients per year and performs 75-100 inductions per month. Highland is a low threshold ED-based program offering 24/7 access to buprenorphine for people in withdrawal or with OUD who are seeking help. This program distinguishes itself in two ways. The program has a universal access policy -- ED patients are not asked if they struggle with substance use, instead, there are publicly placed signs in the ED and patients self-identify when they want help with substance use. The program also proactively reaches out to a local community of providers who are in touch with individuals with OUD, and serves as a 24/7 resource for those centers to refer patients (e.g., detox programs, residential treatment programs, and primary care providers without access to buprenorphine prescribers, or who do not feel comfortable treating people with OUD).

### Information sources

Data for this case study was collected through interviews with individuals in the following roles:

- ED physician.
- SUD navigator.
- Hospital social worker.
- Community partner.

The team also reviewed the following documents shared by Highland Hospital:

- Program data and reports.

### Description of the program

#### History of the program

In January 2017, Dr. Herring proposed offering medication treatment for opioid use based on the D’Onofrio study. Prior to this buprenorphine was not readily available in the Highland Hospital ED. Dr. Herring recruited a staff member to help with the program. Initially, the program was staffed with one ED physician and one navigator. The first patients were in February 2017. As the program grew, additional staff and follow-up capacity were added.

The ED at Highland Medical Center provides a low threshold program focused on 24/7 access to buprenorphine for people in withdrawal or with OUD who are seeking help. Follow-up is facilitated through a bridge program affiliated with Highland Hospital and located near the ED. The bridge program employs clinicians and SUD navigators in an on-site clinic. The bridge program takes the initial follow-up appointment so that the ED has a reliable single point of referral. The program takes patients with few rules and restrictions/requirements, and then transfers them to long-term care only if that is what they want; patients can also choose primary care or be kept within the program.

#### Size

Highland Hospital ED administers buprenorphine in the ED approximately 75-100 times per month, and treats about 600 patients each year making it among the largest programs of its kind in the country.

#### Approach to patient identification

Highland Hospital uses a universal access policy instead of screening individuals. Patients are not asked in triage if they struggle with substance use. There are publicly placed signs before entry to the ED which state “If you are struggling with pills or heroin, we can start you on buprenorphine today.” Signs and posters about the program are also in triage, in the urgent care stalls, in the ED. Staff including greeters and physicians wear pins advertising the program.

Nurses and staff know to page or call the Bridge program if they think someone might need support. Navigators are on-shift from 7:30 AM-7 PM. All providers and nurses have Bridge’s information to get help after hours.

#### Mode of initiating engagement with patients

About 90 percent of inductions occur in a fast-track area that is run by physician assistants and other providers. There is an on-site SUD treatment program (the bridge clinic) funded and organized by the state Medicaid carveout and staffed with ED physicians. The bridge clinic takes care of all follow-up treatment.

#### Program structure and key staff

Buprenorphine is available 24/7 in the ED and navigators are on site from 7:30 AM-7 PM Monday-Friday. After hours doctors and nurses know what to do. They will start the patient on medication treatment and get a phone number or give instructions for returning to the bridge clinic if patient does not have phone.

Navigation and MOUD services available in all parts of hospital, not just ED; expanded to all SUDs.

ED staff include two physicians, and nurses and a navigator. A hospital social worker also supports patients.

The bridge clinic is an extension of the ED. It is staffed with ED physicians, navigators and medical students in training. The bridge clinic has three providers, a social worker, and navigators.

#### Relationship with community partners

- The program proactively reaches out to local providers who are in touch with individuals with OUD, and acts as a 24/7 resource to initiate treatment for those centers (e.g., ex-detox programs, residential tx, primary care providers with no access to prescribers, or who do not feel comfortable treating those patients).
- There is a county phone line which immediately directed to Highland clinic.

#### Financing and sustainability

The Bridge clinic itself is grant-funded. All navigators are grant-funded. California Medicaid will start funding navigators and allow them to bill through the ED, but this is a new policy. California operates a Behavioral Health pilot program, providing $50,000 for each hospital to fund a navigator.

### Barriers and Facilitators to offering ED-based OUD treatment

Respondents identified several facilitators and features that contribute to program success:

- Culture change -- offering a patient-centered and respectful approach to treating OUD.
- An ED champion who is passionate, knowledgeable and wants to share.
- Close collaboration between ED an bridge clinic with smooth referral system.
- Navigators really help the system/provider.
- Universal access without screening -- this approach decreases stigmatizing and keeps individuals from divulging information about themselves which can cause harm objectively due to the existing stigma.
- Really meeting people where they are and getting them into the program; at whatever level the patient wants.

The following barriers were mentioned:

- Provider hesitancy to provide medication treatment.
- Restrictive policies about which patients can received medication for OUD.
- Treatment protocols developed in a research setting.
- The historic idea that ED should not be involved in long-term care.
- Funding, especially for navigators.
- System requirements that are burdensome and/or restrictive (e.g., intakes that require 2-3 hours, difficult for someone in withdrawal or under the influence to complete, required to terminate patients who do not maintain engagement for 30 days).
- Insurance barriers and high out-of-pocket costs.

## NY MATTERS Case Study Summary

### Snapshot of the program

NY MATTERS (Medication Assisted Treatment and Emergency Referrals) (https://mattersnetwork.org/) is a scalable, flexible addiction referral network to facilitate efforts to initiate medication treatment for OUD by connecting patients starting OUD treatment with ongoing outpatient care. The program started in a Buffalo, New York and now supports EDs and other partners across the state. Key aspects of the NY MATTERS program are emergency physician leadership, a range of non-traditional partnerships, a harm reduction approach, and an efficient statewide referral network using an electronic platform that connects patients starting OUD treatment with ongoing community-based treatment services including telemedicine services.

### Information sources

Data for this case study was collected through interviews with individuals in the following roles:

- ED physicians.
- Program administrator.
- Community partners including sheriff and pharmacy representatives.
- State health department representative.

The team also reviewed the following documents shared by NY MATTERS and their partners:

- NY MATTERS Mission, Vision, Values Statement.
- NY MATTERS background materials.
- Sample patient discharge instructions.
- PowerPoint presentations about NY MATTERS and community partnerships.
- NY MATTERS website.

### Description of the program

#### History of the program

The NY MATTERS program was started as Buffalo MATTERS in late 2017 by ED physicians, Joshua Lynch and Brian Clemency, who realized patients with OUD were not getting the care they needed. Prior to starting this effort patients with OUD in the Buffalo ED received information about outpatient treatment programs, but did not receive mediation treatment with buprenorphine or specific referrals. To start the program the ED physicians obtained buprenorphine waivers and developed relationships and agreements with three community providers to coordinate next day follow-up care.

The team also developed a relationship with New York State Department of Health. The goal was to create a nimble, scalable effort; to that end NY MATTERS is not tied to a particular ED, clinic, or hospital network. An electronic referral platform was developed and launched in June 2019. Through partnerships with additional hospitals, outpatient programs, and others including criminal justice system, the program has grown and expanded beyond the Buffalo area and is currently working on expanding into additional areas.

#### Size

The program works with EDs across the state and maintains a database of 250 weekly appointments for initial follow-up across New York State.

#### Approach to patient identification

The approach to identifying patients varies across sites that use the NY MATTERS program. Each hospital decides their own criteria; NY MATTERS provides flexible guidance. The program also partners with courts, correctional facilities, police departments, emergency medical service providers, and other organizations to help connect people with medication treatment through NY MATTERS.

#### Mode of initiating engagement with patients

Patients who start medication treatment are connected with ongoing outpatient treatment through an electronic platform available online and often accessed via an iPad. Patients are able to choose outpatient follow-up care at one of the participating partner sites.

All community partners sites participating in NY MATTERS are required to sign on to the Mission, Vision, Values document. This document requires, for example, that community providers accept patients regardless of insurance status, accept patients who have not been prescribed buprenorphine in the past, and not automatically disqualify patients who engage in polysubstance use, offer timely appointments to people referred by the ED, and not exclude patients or discharge patients who are using drugs other than opioids.

#### Program structure and key staff

The NY MATTERS program is a scalable addiction treatment referral network that operates in collaboration with hospital EDs and other providers or settings who want to start people with OUD on medication treatment and help them connect to care. NY MATTERS is run by a program administrator and two ED physicians; the state hosts the NY MATTERS website and database and provides information technology support. Each participating region has a champion regional coordinator responsible for coordinating outpatient treatment availability. Within each hospital there are different approaches to staffing which may include peer navigators. The program uses telemedicine extensively for referring patients and for providing ongoing care via telemedicine services. All NY MATTERS participating organizations are required to sign on to the NY MATTERS Mission, Vision, Values document which requires, for example, that hospitals prescribe buprenorphine when appropriate based on NY MATTERS guidelines and not automatically disqualify patients if they engage in polysubstance use.

#### Relationship with community partners

NY MATTERS has relationships with community partners who provide outpatient treatment. NY MATTERS works with the Erie County Department of Health, which employs peer navigators who are responsible for conducting follow-up with patients from the Buffalo ED at the 30-60-90 day marks. NY MATTERS partners with Walgreens to administer vouchers for patients that cover the cost of copayments for buprenorphine which are paid for through state STR grant funding.

#### Financing and sustainability

NY MATTERS has funding from New York State Department of Health and the Erie County Health Department available because of grants from SAMHSA and the Centers for Disease Control and Prevention.

### Metrics and measures of success

NY MATTERS partners with the state department of health which conducts overdose detection using syndromic surveillance reports. When spikes in overdose are identified the state reaches out to the local health department and hospitals to determine whether the NY MATTERS program or other resources might be able to help.

NY MATTERS tracks who is administered buprenorphine in the ED and who receives a prescription for buprenorphine. The program is developing a system that would allow tracking of initial visits with outpatient care, but this is difficult because of the large number of clinic partnerships. Regional care coordinators are starting to track patient treatment engagement at two, six, and nine months, but resources to do this are limited. NY MATTERS has also collected patient success stories.

### Barriers and Facilitators to offering ED-based OUD treatment

Respondents identified several facilitators and features that contribute to program success:

- Lab tests are not required to determine if a patient is a good candidate. Removing those barriers at the provider and clinic level have been essential to maintain access to treatment.
- Patient choice of outpatient clinic location and if they get attached to a peer or not.
- Support from New York State which runs the NY MATTERS website has been very helpful.
- The electronic platform that tracks outpatient appointment availability is flexible. As circumstances at each site change appointment availability in the platform is adjusted. For example, a program may offer two slots every Monday and Wednesday and the program administrator checks in with them if they need to change their availability.
- Community champion.
- Having an ED physician speak to the advantages of the program has helped NY MATTERS expand. ED physicians need to hear from peers to buy-in.
- Willingness to work with community partners outside regular silos; non-traditional relationships (e.g., with health departments, hospitals, prisons and jails) and flexibility are essential.
- NY MATTERS does not charge partners or patients which has facilitated expansion. The scalability of the NY MATTERS program makes it an efficient use of funding which appeals to funders.

The following barriers were mentioned:

- Providers have expressed concern about how to dose buprenorphine. In response NY MATTERS identified a standard dose which was very helpful to providers.
- Stigma among community members.
- Transportation barriers can make it difficult for patients to pick up medication.
- The NY MATTERS’ Mission, Vision, Values document was a barrier because each clinic has their own way of doing things. However, it was important to maintain in order to ensure patient access to treatment.
- Hospital and ED concern that offering medication treatment for OUD would interfere with patient flow and take too much time.
- Buprenorphine waiver requirements for emergency medicine staff.
- Cost of medication; partnership with pharmacists in the region and grant funding has been critical to overcome.
- Insurance company preferences for certain buprenorphine formulations put pressure on the program to change medications which is very difficult; however, the issue was eventually resolved through conversations between NY MATTERS, New York State Department of Health, and the insurance companies.
- Challenging to assemble and maintain data from a large number of clinics, makes analysis of impact difficult.

## Anchor ED Case Study Summary

### Snapshot of the program

Anchor ED is a statewide treatment intervention program for OUD in Rhode Island. The program was created by the Providence Center, the Rhode Island Department of Health, the Rhode Island Department of Behavioral Health, Developmental Disabilities and Hospitals and Anchor Recovery Community Centers. It connects individuals admitted to any Rhode Island hospital ED for an opioid-related overdose, or any substance use related issue (including alcohol), with trained Peer Recovery Coaches.

In response to Rhode Island’s high rate of overdose fatalities, Anchor ED was established in 2014 by two motivated co-founders to engage peer support specialists with patients at the point of overdose in the ED. Anchor ED Peer Recovery Coaches are available on call to speak with patients and are trained professionals with lived experience. Anchor ED partners with 11 EDs across the state. The program has expanded to offer recovery support for other SUDs and works primarily with the Anchor Recovery Community Center and additional recovery centers to connect individuals with care close to where they live. Anchor ED has now served as a model for numerous other programs addressing SUD in the ED.

### Information sources

Data for this case study was collected through interviews with individuals in the following roles:

- State Health Department executive (co-founder).
- Program liaison.
- Providence Center senior executives.
- Anchor ED manager.
- Operations manager.
- Hospital administrator.
- ED physicians.
- Peer support specialist.

The team also reviewed the following documents shared by Anchor ED:

- Program data and reports.
- Data from the Rhode Island Department of Health describing referrals.
- Public descriptions of the program.

### Description of the program

#### History of the program

The program was started with seed money from the Rhode Island Department of Behavioral Health. The co-founders engaged in meetings and negotiations with hospitals, discussing the devastation caused by the opioid epidemic, devised a plan and started with Rhode Island Hospital with support from a program champion ED physician. The co-founder found that the ED physician’s advocacy was key to convincing the ED to allow peer recovery coaches in the hospital.

The Anchor ED model is one of the first of its kind. The program is primarily community-based out of the Providence Center (https://anchorrecovery.providencecenter.org/), unlike many programs that are hospital-based and managed. The Providence Center has provided guidance to many other states and hospital systems, and has also received international visits from representatives from Vietnam and Canada.

#### Size and patient population

In Anchor ED’s first year, peer recovery coaches had contact with 1,329 patients. In a recent quarter, according to program reports, the Anchor ED responded to 185 total calls and 181 unique individuals. In a recent quarter, 128 individuals seen through Anchor ED were not current already connected with substance use or mental health treatment.

#### Approach to patient identification

The program has both Providence Center based and ED dedicated peer specialists. Specialists are dispatched through the Anchor ED call-center in response to service requests in the ED. In most cases, clinicians identify patients admitted to the ED for an overdose and those who are good candidates for OUD treatment.

Clinicians ask patients if they want to meet with a peer recovery coach, and if they are interested, Anchor ED is called and a specialist arrives within 30 minutes. Patients can then engage in same-day treatment.

#### Mode of initiating engagement with patients

The program is not widely advertised in the ED to patients. However, the Anchor ED contact information is posted and visible to ED staff. Each hospital varies with either clinicians or social workers handling coordination with Anchor ED services. Anchor ED stays in touch with patients for ten consecutive days whether or not they initially choose to engage in treatment. As an example, a patient who initially refused treatment contacted the program to start treatment six months later.

Each hospital follows its own set of guidelines about who can induct patients and when to do so. The program offers all paths to recovery that are available, including but not limited to MOUD: it is based on patient preference. Some hospitals will do an immediate induction. Peer specialist assignments factor in proximity to the patient’s home. During COVID-19, hospitals used telemedicine to start on medications and then refer patients for continuity.

According to a recent report, of the 1,441 overdose survivors seen by recovery specialists in 2019 1,322 or 91.7 percent, engaged in recovery supports after discharge from the ED.

#### Program structure and key staff

Peer recovery specialists generally assist in helping to coordinate with the hospital or community partners to a facilitate a patient warm-handoff. They offer a combination of on-site peer recovery support, introduction to the recovery planning process, referrals to substance use and mental health treatment, education and training on naloxone, and more. Specifically, peer recovery specialists link individuals to treatment and recovery resources, provide education on overdose, prevention and on obtaining naloxone, provide additional resources to individuals and family members, and contacting individuals to follow up after they are released from the ED. While recovery specialists are not embedded in the ED, they are available in rapid time: according to program reports, peer specialists in 2020 took 22 minutes to get to the hospital after receiving a call.

Anchor ED makes consistent efforts to develop relationships with ED staff. The program partners with 11 EDs across the state to provide 24 hour service. Anchor ED calls partner hospitals each day at the beginning of each shift to check in with ED staff to identify new patients. There is also a mobile team known as Anchor MORE (Mobile Outreach Recovery Efforts) which is a “boots on the ground” initiative to connect individuals to treatment and recovery supports.

#### Relationship with community partners

The program works with several community partners. Patients started on MOUD in the ED or hospital are connected with Anchor Recovery Community Center (primary), or locations to connect individuals with care close to where they live.

Anchor also engages in a number of additional supporting outreach activities, such as continuing education at hospitals about services offered, to get stakeholder feedback, participating in statewide development of protocols for post-overdose care, and is represented on several governor’s committees addressing behavioral health and treatment.

#### Financing and sustainability

Anchor ED operates using SAMHSA funding and state-based funding through the Rhode Island Department of Behavioral Healthcare, Developmental Disabilities and Hospitals (BHDDH). Medicaid expansion has played an important role in sustaining the program through block grant funding.

The program continues expansion of its capacity to offer SUD recovery services beyond OUD. Anchor ED has communicated with the Rhode Island BHDDH to determine its path forward. While its contract has not formally changed, the program does offer recovery support for all SUDs.

#### Metrics and measures of success

Several measures are reported by Anchor ED on a quarterly basis. This includes patient demographics, response time, types of substances, and program activities. A recent quarterly (October-December 2020) report includes the following:

- The Anchor ED responded to 185 total calls and 181 unique individuals, 128 of them were not currently in treatment.
- 159 Recovery Plans were completed with individuals seen through Anchor ED.
- Each individual seen through Anchor ED was asked if they would like to continue with peer recovery support services after discharge:
  ○ 175 wanted to continue to with peer recovery supports after discharge.
  ○ 175 individuals agreed to a referral to treatment services such as detox, intensive outpatient, recovery housing and medication-assisted treatment programs.
- 90 individuals agreed to begin medication-assisted treatment and were connected with potential providers.
- Anchor ED Peer Recovery Specialists provided Naloxone training to 158 individuals seen through the ED.
- Success Stories from the quarterly report:
  ○ An Anchor ED Peer Recovery Specialist was able to secure a bed at Butler Hospital for individual seen in the emergency room. However, they did not have transportation to Butler Hospital and were being discharged from the emergency room. The Peer Recovery Specialist was able to coordinate transportation to Butler with the Anchor MORE team and stayed with the individual in the hospital waiting room until Anchor MORE arrived.
  ○ Anchor ED recently hired a new Peer Recovery Specialist who received services through Anchor ED in the past. The early connection with a Peer Recovery Specialist at the hospital inspired the individual to pursue a career in the field. The new staff member is scheduled to begin in January 2021.

#### Barriers and Facilitators to offering ED-based OUD treatment

The following barriers were mentioned:

- Stigma (among both providers, patients, community).
- Lack of knowledge about OUD treatment options and their effectiveness.
- Turnover among ED staff leads to new staff unfamiliarity with peer specialists.
- X-Waiver requirements.
- Lack of insurance coverage for some services, requiring continued reliance on grant funding.
- Low reimbursement rates for SUD treatment.
- COVID-19 restrictions.
- Transportation and housing difficulties for patients.

Respondents identified several facilitators and features that contribute to program success:

- Champion with passion and drive.
- Patient-centered program.
- Low-barrier program.
- Peer recovery specialist initial and continued attention to patients.
- Consistent and welcoming approach.