# Appendix 1 Metrics used to examine effectiveness of ED-based OUD treatment

Measure | Data Source | Study
ED-based medication initiation studies
Patient experience measures
Patient experience | Patient self-report | Snow 2019
Process measures
Engagement in formal outpatient addiction treatment at various timepoints (e.g., 30 days, 2 month, 6 month, 12 month follow-ups) | Clinician report; Clinician report; System EMR; Outpatient tx pgm | D’Onofrio 2017; D’Onofrio 2015; Dunkley 2019; MA HPC 2018
Initial follow-up with outpatient treatment | System EMR | Dunkley 2019
HIV risk assessment score | Patient self-report | D’Onofrio 2017
Wait time for outpatient treatment | Primary data collection | Kawasaki 2019
Outcome measures
Number of days of illicit opioid use in the past 7 days | Patient self-report | D’Onofrio 2017
Opioid-negative urine test results (2 months and 6 months) | Primary data collection | D’Onofrio 2017
Mortality | Hospital EMR | MA HPC 2018
Lethal and non-lethal overdose | Hospital EMR | MA HPC 2018
Structural measures
Number of newly waivered providers | Primary data collection | Kawasaki 2019
Provider knowledge and ability to provide OUD treatment | Primary data collection (survey) | Kawasaki 2019
ED 30 day revisit | Hospital EMR | MA HPC 2018
6 month ED utilization rates | Chart review | Sullivan 2021
Peer Support Studies
Process measures
Engaged in medication treatment (initial and 6 month) | Private insurance & Medicaid claims | Watson 2020
Engagement with a formal SUD treatment program within 30 days of the initial ED visit | State SUD administrative data & PDMP Data | Goedel 2020
Initiation of OUD medication | State PDMP Data | Samuels 2018
Outcome measures
Recurrent ED visit(s) for a suspected opioid overdose over 18 months | Statewide EMR & Denver Health and Hospitals Authority Surveillance Data | Goedel 2020
ED visit for overdose | Statewide EMR | Samuels 2018
1 year mortality | State Vital Records Database; National Death Index | Samuels 2018

EMR: Electronic medical record; PDMP: prescription drug monitoring program