# REFERENCES

AARP Foundation. (n.d.) Connect2Affect. https://connect2affect.org/.
Administration for Community Living (ACL). (2021). BE WITH: Training volunteers to support at-risk older adults. https://acl.gov/news-and-events/acl-blog/be-training-volunteers-support-risk-older-adults.
Administration for Community Living (ACL). (2021). 2020 Profile of Older Americans. https://acl.gov/sites/default/files/Aging%20and%20Disability%20in%20America/2020ProfileOlderAmericans.Final.pdf.
Administration on Aging (AoA) and Substance Abuse and Mental Health Services Administration (SAMHSA). (2016). Older Americans Behavioral Health Issue Brief 4: Preventing Suicide in Older Adults. https://acl.gov/sites/default/files/programs/2016-11/Issue%20Brief%204%20Preventing%20Suicide.pdf.
Ahmedani, B.K., Simon, G.E., Stewart, C., Beck, A., Waitzfelder, B.E., Rossom, R., … & Solberg, L.I. (2014). Health care contacts in the year before suicide death. Journal of General Internal Medicine, 29(6), 870–877.
Alexopoulos, G.S., Reynolds, C.F. III, Bruce, M.L., Katz, I.R., Raue, P.J., & Mulsant, B.H. (2009). The PROSPECT Group: Reducing suicidal ideation and depression in older primary care patients: 24-month outcomes of the PROSPECT study. American Journal Psychiatry, 166: 882–890.
American Association of Suicidology (AAS). (2020). Recognizing and Responding to Suicide Risk: Essential Skills for Clinicians. https://suicidology.org/training-accreditation/rrsr-clinicians/.
Armitage, R., & Nellums, L.B. (2020). COVID-19 and the consequences of isolating the elderly. Lancet Public Health, 5(5): e256. doi:10.1016/S2468-2667(20)30061-X.32199471
Banerjee, D., Kosagisharaf, J.R., & Sathyanarayana Rao, T.S. (2021). ‘The dual pandemic’ of suicide and COVID-19: A biopsychosocial narrative of risks and prevention. Psychiatry Res, 295: 113577. doi: 10.1016/j.psychres.2020.113577.33229123
Betz, M., Arias, S., Segal, D., Miller, I., Camargo, C., & Boudreaux, E. (2016). Screening for suicidal thoughts and behaviors among older patients visiting the emergency department. Journal of the American Geriatrics Society, 64(10): 72–77.
Bruce, M., & Pearson, J. (2022). Designing an intervention to prevent suicide: PROSPECT (Prevention of Suicide in Primary Care Elderly: Collaborative Trial). Dialogues in Clinical Neuroscience, 1(2): 100–112.
Centers for Disease Control and Prevention (CDC), National Center for Health Statistics. (2021). Underlying Cause of Death 2018-2020 on CDC WONDER Online Database. http://wonder.cdc.gov/ucd-icd10-expanded.html.
Conejero, I., Olie, E., Courtet, P., & Calati. R. (2018). Suicide in older adults: Current perspectives. Clinical Interventions in Aging, 13: 691–699.29719381
Conwell, Y. (2013). Suicide and suicide prevention in later life. Focus, 11(1): 39–47.
Conwell, Y., Van Orden, K., & Caine, E.D. (2011). Suicide in older adults. Psychiatric Clinics of North America, 34(2): 451–468. 10.1016/j.psc.2011.02.002.21536168
Dahlberg, L. (2021). Loneliness during the COVID-19 pandemic. Aging Ment Health. 10.1080/13607863.2021.1875195.
Drapeau, A., Boyer, R., & Lesage, A. (2009). The influence of social anchorage on the gender difference in the use of mental health services. Journal of Behavioral Health Services & Research, 36(3): 372–384.19252987
Gerst-Emerson, K., & Jayawardhana, J. (2015). Loneliness as a public health issue: The impact of loneliness on health care utilization among older adults. Am J Public Health, 105(5): 1013–1019. doi:10.2105/AJPH.2014.302427.25790413
Hedegarrd, H., Curtin, S., & Warner, M. (2018). Suicide mortality in the United States, 1999-2017. NCHS Data Brief, no. 330. https://www.cdc.gov/nchs/products/databriefs/db330.htm.
Hinton, Zweifach, Oishi, Tang, & Unützer. (2006). Gender disparities in the treatment of late-life depression: Qualitative and quantitative findings from the IMPACT trial. Am J Geriatric Psychiatry, 14(10):884–892.
Holt-Lunstad, J. (2021). A pandemic of social isolation? World Psychiatry, 20: 55–6. 10.1002/wps.20839.33432754
Institute on Aging. (n.d.). Center for Elderly Suicide Prevention. https://www.ioaging.org/services/psychological-services/center-for-elderly-suicide-prevention.
Kiosses, D.N., Rosenberg, P.B., Mcgovern, A., Fonzetti, P., Zaydens, H. & Alexopoulos, G.S. (2015). Depression and suicidal ideation during two psychosocial treatments in older adults with major depression and dementia. Journal of Alzheimer’s Disease, 48: 453–462.
Kognito. (2022). At-Risk in Primary Care. https://store.kognito.com/products/primary-care.
Lapierre, S., Erlangsen, A., Waern, M., . (2011). A systematic review of elderly suicide prevention programs. Crisis, 32(2): 88–98. doi:10.1027/0227-5910/a000076.21602163
Okolie, C., Dennis, M., Simon Thomas, E., & John, A. (2017). A systematic review of interventions to prevent suicidal behaviors and reduce suicidal ideation in older people. Int Psychogeriatr, 29(11): 1801–1824. doi:10.1017/S1041610217001430.28766474
O’Rourke, M.C., Jamil, R.T., & Siddiqui, W. (2022). Suicide screening and prevention. In StatPearls. StatPearls Publishing. http://www.ncbi.nlm.nih.gov/books/NBK531453/.
Question, Persuade, Refer Institute. (2013). QPR for Physicians, Physician Assistants, Nurse Practitioners, and Others. https://courses.qprinstitute.com/index.php?option=com_zoo&task=item&item_id=14&Itemid=739.
SafeSide Prevention. (n.d.). SafeSide Primary CARE. https://safesideprevention.com/programs/primary-care.
Saunders, H. & Panchal, N. (2023). A Look at the Latest Suicide Data and Change Over the Last Decade. https://www.kff.org/mental-health/issue-brief/a-look-at-the-latest-suicide-data-and-change-over-the-last-decade/.
Substance Abuse and Mental Health Services Administration (SAMHSA). (2019). 2019 National Survey of Drug Use and Health (NSDUH) Releases. https://www.samhsa.gov/data/release/2019-national-survey-drug-use-and-health-nsduh-releases.
Substance Abuse and Mental Health Services Administration (SAMHSA). (2019). Older Adults Living with Serious Mental Illness: The State of the Behavioral Health Workforce. https://store.samhsa.gov/sites/default/files/d7/priv/pep19-olderadults-smi.pdf.
Substance Abuse and Mental Health Services Administration (SAMHSA). (2015). Promoting Emotional Health and Preventing Suicide. https://store.samhsa.gov/sites/default/files/d7/priv/sma15-4416.pdf.
Suicide Prevention Resource Center (SPRC). (2017). Suicide Prevention Toolkit for Primary Care Practices. https://www.sprc.org/sites/default/files/Final%20National%20Suicide%20Prevention%20Toolkit%202.15.18%20FINAL.pdf.
Suicide Prevention Resource Center (SPRC). (2015). The Role of Senior Living Community Professionals in Preventing Suicide. https://sprc.org/sites/default/files/resource-program/SrLivingCommunity_providers.pdf.
Thomas, K.S., Akobundu, U., & Dosa, D. (2016). More than a meal? A randomized control trial comparing the effects of home-delivered meals programs on participants’ feelings of loneliness. Gerontological Society of America, 71(6).
United Nations. (2020). Policy brief: The impact of COVID-19 on older persons. New York, NY. https://unsdg.un.org/sites/default/files/2020-05/Policy-Brief-The-Impact-of-COVID-19-on-Older-Persons.pdf.
Unützer, J., Katon, W., Callahan, C., Williams, J., Hunkeler, E., & Harpole, L. (2002). The IMPACT investigators. Collaborative care management of late-life depression in the primary care setting: A randomized controlled trial. Journal of the American Medical Association, 288: 2836–2845. [PubMed:12472325.]12472325
Unützer, J., Tang. L., Oishi, S., Katon, W., Williams, J., & Hunkeler, E. (2006). The IMPACT investigators. Reducing suicidal ideation in depressed older primary care patients. Journal of the American Geriatrics Society, 54: 1550–1556. [PubMed: 17038073.]17038073
Van Orden, K., & Conwell, Y. (2016). Issues in research on aging and suicide. Aging Ment Health, 20: 240–251.26179380
Waern, M. (2003). Alcohol dependence and misuse in elderly suicides. Alcohol, 38(3): 249–254.
Wallace, M., Miller, V.J., Fields, N.L., Xu, L., & Mercado-Sierra, M.A. (2021). Empirically evaluated suicide prevention program approaches for older adults: A review of the literature from 2009-2021. J Gerontol Soc Work, 64(5): 480–498. doi:10.1080/01634372.2021.1907495.33830893
Zero Suicide Institute. (n.d.) Suicide Prevention in Primary Care: A Toolkit for Primary Care Clinicians and Leaders. https://zerosuicide.edc.org/sites/default/files/%20suicidesafercareguideforprimarycareproviders.pdf.