# EXECUTIVE SUMMARY

Despite the increasing evidence of high suicide rates and associated risk factors for older adults in the United States, the number of programs addressing these risk factors remains limited. The Office of the Assistant Secretary for Planning and Evaluation contracted with RTI International to conduct an environmental scan and convene a technical expert panel (TEP) to identify existing and effective suicide prevention interventions, how these interventions can be expanded to the older adult population, and the barriers to tailoring existing programs to older adults.

The results of the environmental scan suggest that programs aimed at decreasing the risk of suicide ideation are more likely to reduce risk factors than they are to improve protective factors. Effective interventions include primary care-based programs, community programs, group activities, and telephone counseling. However, few evidence-based programs are currently available that aim specifically to prevent suicide among older adults, and research into program effectiveness among older adults is limited. The most recent evaluations of the evidence-based programs included in this report date back over a decade. As the baby boomer generation ages, further research is needed to assess the effectiveness of current suicide interventions specifically for older adults.

Barriers identified in the environmental scan reflect the difficulty of tailoring existing programs for older adults. For example, older adults experience unique stressors, which are not well addressed in all suicide screening tools; such risk factors include involuntary retirement, social isolation, thwarted belongingness (feeling that one’s need to belong is unmet), perceived burdensomeness (feeling of one being a burden to others), sadness after the loss of a spouse or partner, and declining health. As suicide risk assessments are often used in intervention programs, they could be better targeted to older adults by addressing these risk factors. Additionally, research on the effectiveness of programs delivered via telecommunication is lacking for older adults.

In June 2022, we convened a TEP consisting of clinical psychologists, psychiatrists, university professors, and public health professionals specializing in geriatric behavioral health and/or suicide prevention. The panelists participated in a discussion on currently available suicide prevention interventions for both the general public and older adults specifically, as well as barriers to implementation of these interventions. Of the currently available interventions for older adults, those that emphasize social connections are associated with decreased suicide ideation. However, the panelists agreed that a lack of funding and competing research priorities (e.g., younger adult suicide) limit further development of such programs. Further, the panelists stressed that the COVID-19 pandemic created an opportune time to emphasize the importance of mental health care, as mental health began to be more frequently discussed and less likely to be stigmatized This increased focus on mental health has persisted since the end of the COVID-19 public health emergency, and the window of opportunity to improve or expand mental health care remains open.

The key takeaways from both the environmental scan and TEP suggest that much more research is needed on suicide risk factors and stressors unique to older adults, signs of suicide ideation, and effective prevention strategies for older adults. Such research is especially urgent given that older adults are at such high risk of death by suicide. Regarding suicide prevention programs and interventions, stakeholder collaboration is needed in order to create a standard intervention that addresses multiple behavioral health factors, including suicide ideation. This intervention should be tailored to appropriately address the needs of the older adult. Additionally, policies that eliminate or alleviate barriers to appropriate care and services are needed.