# ACRONYM

The following acronyms are mentioned in this report and/or appendices.

AAS: American Association of Suicidology
ACL: Administration for Community Living
AoA: Administration on Aging
CDC: Centers for Disease Control and Prevention
COVID-19: Novel Coronavirus
IMPACT: Improving Mood-Promoting Access to Collaborative Treatment
PATH: Problem Adaption Therapy
PROSPECT: Prevention of Suicide in Primary Care Elderly: Collaborative Trial
QPR: Question, Persuade, Refer Institute
SAMHSA: Substance Abuse and Mental Health Services Administration
SPRC: Suicide Prevention Resource Center
ST-CI: Supportive Therapy for Cognitively Impaired Older Adults
SUD: Substance Use Disorder
TEP: Technical Expert Panel
USDA: U.S. Department of Agriculture
VA: U.S Department of Veterans Affairs