# SECTION 4 CONCLUSIONS

This project aimed to identify existing programs addressing older adult suicide as well as opportunities to expand those programs, and barriers to implementing and sustaining existing programs. Through our environmental scan and TEP, we identified unique risks, unmet needs, key barriers to serving the population well, and areas where further research is needed.

Older adults face unique suicide risk factors, such as involuntary retirement, social isolation, thwarted belongingness, loss of a spouse or partner, and declining physical and cognitive health. Homelessness, access to firearms, limited transportation, and limited access to the internet and technology can also contribute to suicide risk and serve as barriers to treatment for older adults. Some of these risk factors are not included in many clinical assessments but could be an area of opportunity for clinical providers to identify suicide risk among their patients. In order for clinical assessments to be utilized and maintained by providers, these assessments should be built directly into the regular workflow for engaging with patients. Outside of exclusively clinical interactions, effective suicide prevention programs for older adults emphasize building social connections and reducing loneliness. Examples of such programs include Care Partners, the 988 Suicide and Crisis Hotline, Senior Connection, and Connection Planning. Many of these programs are telephone-based; however, with technology continually evolving, fewer new programs rely on the basic phone services used by older generations. Lack of availability and reliability of phone services can also reduce access to these programs and also serve as a barrier to treatment. Ensuring that phone service is offered or that training on unfamiliar technologies is administered can mitigate these challenges.

Interest and funding for research on suicide prevention in older adults has been limited to date. Expansion of research and funding is necessary to ensure programs address the unique barriers and specific needs of this age group. Not only does funding pose a challenge for program expansion and research, but members of the TEP also identified ways in which existing Medicare coverage and reimbursement policies may directly impact older adults themselves. Medicare’s provider reimbursement policies may limit provider willingness to participate in Medicare, reducing access to necessary screenings and treatment, according to some members of the TEP. In addition, Medicare cost sharing requirements may result in older adults not seeking treatment, and also reduce patient follow-up. Some TEP members encouraged policymakers to work directly with health care providers delivering mental health assessments to better understand and incorporate what patients and providers need from Medicare.

Stakeholders and decisionmakers are currently discussing mental health care and related policies with an increased sense of urgency due to the negative impacts of the COVID-19 pandemic and social distancing on individual’s mental health across all ages. Policymakers should leverage this ongoing public attention to better meet mental health needs, including those of older adults.

The findings from this study can be used to inform future efforts to develop, implement, and tailor programs and policies that support suicide prevention among older adults; however, we encourage further research on older adult suicide, barriers to accessing programs, and challenges in implementing programs. Of particular interest is obtaining a better understanding of the unique stressors and symptoms experienced by older adults at risk of suicide. In terms of improving prevention efforts, changes can be made in existing systems, including improvements to clinical workflows to include routine screenings and assessments, as well as Medicare provider reimbursement amounts and coverage policies. One critical strategy will be bringing stakeholders, including clinicians, patients, and policymakers, together to collaboratively build interventions that addresses multiple behavioral health factors, including suicide ideation. These interventions should be customizable so they can appropriately address the varied needs of older adult patients. This work is especially important given that older adults more frequently die by suicide when it is attempted, a trend that is continuing, and may even be growing, in the post-COVID-19 pandemic context (Saunders & Panchal, 2023).