# SECTION 3 PROFESSIONAL INPUT FROM EXPERT PANELISTS

Panelists for the TEP consisted of clinical psychologists, psychiatrists, university professors, and public health professionals specializing in geriatric behavioral health and/or suicide prevention. The panelists for the TEP are outlined in Exhibit 3.

EXHIBIT 3 List of TEP Panelists

Name | Affiliation | Area(s) of Expertise
Dr. Brian Ahmedani | Henry Ford Health | Suicide prevention research
Dr. Yeates Conwell | University of Rochester | Geriatric psychiatrist
Dr. Amy Fiske | West Virginia University | Depression and suicide in older adults
Dr. Matthew Fullen | Virginia Tech | Disparities in mental health care delivery through Medicare
Dr. Maria Llorente | VA | Geriatric psychiatrist
Dr. Richard McKeon | SAMHSA | Chief of Suicide Prevention; collaborator of the national 988 suicide hotline
Dr. Laura Shannonhouse | Georgia State University | Crisis and disaster response; co-creator of the aging variant of ASIST/BE WITH suicide prevention training
Dr. Deborah Stone | CDC | Suicide prevention through a public health approach
Dr. Katalin Szanto | University of Pittsburgh | Suicide among older adults and age-specific risk factors of suicide
Dr. Jürgen Unützer | University of Washington | Geriatric psychiatrist; principal investigator of the IMPACT study
Dr. Kimberly Van Orden | University of Rochester | Clinical psychologist; interventions to reduce social isolation and loneliness

## 3.1 Available Interventions and Opportunities for Expansion

The first half of the TEP discussion focused on currently available interventions that aim to prevent suicide among older adults, interventions that could be tailored to older adults, and opportunities for expansion of these programs. The programs discussed primarily emphasized building social connections and reducing loneliness. Panelists stressed that the interventions shown to prevent suicide deaths in older people all contain similar components of peer support and connecting. Examples of such programs included Care Partners, the 988 Suicide & Crisis Lifeline, Senior Connection, and Connection Planning. Other programs discussed were provided in U.S. Department of Veterans Affairs (VA) health care systems, community-based settings, and volunteer opportunities for older adults through AmeriCorps Senior. Exhibit B-1, Appendix B, describes the interventions discussed during the TEP.

The panelists spoke to some of these programs’ successes. Overall, the panelists reported that suicide prevention programs are generally effective and that identifying specific helpful components is key. An example program are the Care Partners and Stay Connected programs, the latter being a telephone component added in response to the COVID-19 pandemic. This remote option has been reasonably successful as more older adults could be reached; overall, the program saw an increased proportion of people whose depression improved. Another example of a helpful component came from the Primary Care Mental Health Integration program within the VA health care system. The focus of this component was concomitant communication with a veteran’s primary care or mental health provider after that veteran reached out to the hotline. In the Senior Connection program, receipt of a peer companion significantly improved depression among participants.

“Veterans that engage with the VA health care system have much lower suicide rates than those that don’t engage with the VA…there is now a decline between 2019 and 2021 in the number of veteran suicides.”

– Dr. Maria Llorente

A chain of questions needs to be addressed when expanding existing programs to the older adult population: (1) in what ways can a program focus on the population; (2) what resources are needed to do so; and (3) how community partners can be brought in for support. Panelists discussed partnering with organizations such as Meals on Wheels, food banks, and primary care clinics to encourage eligible older adults to participate in available programs. For example, the Care Partners project creates partnerships between community-based organizations and primary care clinics to address depression in primary care together. Other suggestions included utilizing a tailored depression screening, such as the Masculine Depression Scale, as a way to identify at-risk older men.

However, additional risk factors exist for suicide ideation among older adults beyond a mental health diagnosis. For older veterans in particular, addressing and preventing homelessness is an important component to reducing suicide risk. Suicide prevention programs can also consider reducing access to lethal means, such as firearms, among people at-risk as part of their protocols.

## 3.2 Barriers to Implementation and Ways to Overcome

The second half of the TEP discussion focused on specific barriers to implementing suicide interventions for older adults and ways to overcome those barriers. The panelists shared from their experience and research some of the most common and difficult barriers they have faced while trying to implement such interventions.

The COVID-19 pandemic prompted a rapid transition to virtual care that became a major barrier for some individuals. Panelists felt that although the majority of the population appeared to be adjusting, there continue to be patients left behind who do not have access to or do not use technology in the same capacity as others. Older adults can find navigating the technology challenging and may be unable to utilize virtual care. Such struggles can exacerbate older adults’ perceived burden on their younger family, who they may turn to for assistance. Additionally, although certain programs may be able to supply patients with tablets for care, older adults who reside in rural areas may not have internet access needed to utilize those tablets.

Transportation for health care appointments can pose another barrier. The VA offers a program to cover the cost of taxi cabs, provide a shuttle service, or provide transportation cards for public transportation. However, with the rise of ride share applications availability of traditional taxis has declined, and public transportation is not available in many areas. Likewise, programs that provide van or shuttle rides can be inconvenient for the patient. While these services directly pick up and drop off a patient from their house, it can be a full day affair due to set departure and arrival times. The VA found a patient is more likely to cancel their appointment when using these services. A solution proposed to this barrier was to develop a more person-centered program, allowing older adults to be reimbursed for private transportation through rideshare services.

Location also can influence access to mental health care. Multiple TEP members stated that within rural communities, mental health providers largely do not accept Medicare, reporting that in their view Medicare does not reimburse at a high enough level to be worthwhile. Panelists discussed how to broaden the mental health infrastructure within these communities. It was noted that a one-size-fits-all approach may not be effective in rural locations. Stronger suicide awareness and prevention training is needed across community-based and primary care organizations.

The panelists also discussed financial barriers to program implementation and research. Programs like the Friendship Line are not usually eligible for Medicare reimbursement and must receive funding from public and private grants, which can be challenging to access. Without this external funding, the Friendship Line, and other programs like it, cannot survive. Among programs and interventions that can be reimbursed by Medicare, which according to the TEP and scan tend to be treatment centers or direct providers, older adults may themselves face financial challenges. Although cost-sharing requirements for outpatient mental health care are similar to those of other outpatient services, these costs may still be prohibitive for some older adults seeking mental health care.

“Over 560 Agencies on Aging and 60 American Indian tribal groups [receive] greatly inadequate funding but could be a potential resource [if the] infrastructure and scope of the [health care] system were addressed.”

– Dr. Yeates Conwell

In further discussions of Medicare payment model barriers, panelists noted that policymakers need to work directly with providers delivering services to understand providers’ needs and wants. Others stated that for clinicians to provide high quality clinical services, they need to be reimbursed for those services. Numerous health care priorities are currently competing for programmatic and research funding. Adolescent suicide remains a high priority in mental health policy and research in contrast, fewer resources may be available for interventions and research on suicide prevention in older adults.

At the time of the TEP, panelists unanimously agreed that the COVID-19 pandemic, increased opportunities to facilitate conversations challenging mental health stigma and ageism. Given the lingering harms of COVID-19 and social distancing on individuals’ mental health as well as the resulting increased focus on addressing mental health challenges, these opportunities remain today.. In these conversations, it is important to emphasize that older adult suicide differs from suicide patterns observed in other age groups. Defining these unique challenges and patterns experienced by older adults would elevate this issue and what strategies should be employed for successful interventions. Dr. Van Orden noted that this could be a starting place in developing suicide prevention programs for older adults.

“Preventing suicide in later life is not just about preventing deaths, it’s about treating suicide ideation.”

– Dr. Kimberly Van Orden

Participant engagement can pose a barrier for some programs. For example, a research team evaluating the effectiveness of ASIST found confidentiality issues were a barrier because patients had to share their personal contact information and agree to be audio recorded in order to participate in the trial. The ASIST team overcame this barrier by working with software engineers to create a system called Friendly Buzz. Friendly Buzz enables ASIST volunteers to call into the system but does not disclose the contact information of the older adult.

Leadership turnover in suicide prevention programs is another reported barrier to effective implementation. New staff require continuous training to be kept current with the intervention protocols, which can delay further program implementation. Additionally, inexperienced staff are not as adequately prepared to provide clinical consultation for this specific population of older adults. Within one group using the ZeroSuicide program, a period of high turnover was specifically correlated with an increased suicide rate. A decrease in suicide rates occurred once staffing and leadership stabilized.

Lastly, lack of structure in mental health care delivery was a barrier faced by many panelists. Having the processes and structure built directly into the existing health care workflow is critically important. This ensures providers and staff know the necessary processes and steps to take. Among behavioral health providers, not knowing who to contact, when to do so, and what to do next can lead to inaction. In the panelists’ experience, providers do not screen for mental health disorders in older adults because they may not know what the next steps are if the patient displays symptoms of a disorder. With a structured system, providers are more willing to engage since there is a clear direction to follow. Provider buy-in on the structured system should be obtained. An understanding of treating suicide ideation and knowing the programs that exist to address risk factors is critical to treating older adults. To assist policymakers, providers should develop a model of what suicide prevention should look like in later life.