# SECTION 2 EVIDENCE FROM THE LITERATURE

## 2.1 Methods

RTI conducted an environmental scan using a targeted search of peer-reviewed literature and grey literature from selected sources to identify older adult suicide prevention programs and barriers to program implementation. This search was narrowly tailored to include only those sources focused explicitly on older adult suicide prevention programs. While there were other sources on suicide prevention more broadly in which findings were presented across age groups, older adults were not specifically highlighted; instead, research tended to compare children and youth to adults. With this narrow focus, we identified three systematic reviews of older adult suicide prevention programs for the peer-reviewed literature search (Lapierre et al., 2011; Okolie et al., 2017; Wallace et al., 2021). We expanded the search to other peer-reviewed work referenced in the reviews, focusing on domestic, English-language literature. Additionally, we searched 20 organizations’ websites using key words associated with older adult suicide prevention programs and their implementation to supplement the systematic review findings. The organizations generally fell within the following categories: United States government agencies, condition-specific organizations, and specialty and professional associations. We also considered input from RTI experts experienced in researching suicide prevention.

EXHIBIT 1 Peer-Reviewed Literature Flow Diagram

EXHIBIT 1, FLOW DIAGRAM: This diagram shows the steps taken identify relevant peer-reviewed literature that was used in the environmental scan. The steps are: (1) Identification of potentially relevant literature; (2) Screening of literature via review of abstracts by population focus and relevance; (3) Eligibility determination via full-text reviews; and (4) Inclusion of eligible records in the environmental scan. Thirteen records were initially identified; through this process, 6 records were determined to be eligible and included.

The search of the peer-reviewed literature yielded six full-text references, including the original three systematic reviews; the search of the grey literature yielded eighteen references. See Exhibit 1 for the peer-reviewed literature flow diagram and Exhibit 2 for the list of organizational website terms used in the grey literature search.

EXHIBIT 2 Grey Literature Review: Organizations and Search Terms Used

Organizations | Search Terms
AARP; American Association of Suicidology (AAS); Administration for Community Living (ACL); AIMS Center; Aging Network; Center for Disease Control and Prevention (CDC); Cigna; Education Development Center, Inc.; Institute on Aging; Kaiser Family Foundation; Kognito; LeadingAge; National Association of State Mental Health Program Directors; National Council on Aging; Question, Persuade, Refer Institute (QPR); Safeside Prevention; Substance Abuse and Mental Health Services Administration (SAMHSA); Suicide Prevention Resource Center (SPRC); U.S. Department of Veterans Affairs (VA); ZeroSuicide | older adult* OR Elder* OR Old* Age* Person OR Age* Adult; AND; Suicide OR Suicidal Behaviors OR (Suicide AND Suicidal Behaviors); AND; Program OR Intervention OR Screening; OR; Prevention OR Support Services; OR; Health Insurance OR Payer OR Health plan

We extracted content relevant to each of our study focus areas from the six selected publications and grey literature and entered the information into a data charting tool. We present results by the two focus areas: (1) existing programs and interventions; and (2) barriers to widespread implementation.

## 2.2 Existing Suicide Prevention Programs for Older Adults

We identified several suicide prevention programs targeted to older adults in the published and grey literature reviews. These programs are categorized by their implementation setting: primary care offices, emergency departments, and at home. Exhibit A-1, Appendix A, provides an overview of the interventions described in this section.

### 2.2.1 Primary Care Interventions

Two targeted and research-based programs situated in a primary care setting are Improving Mood-Promoting Access to Collaborative Treatment (IMPACT) and Prevention of Suicide in Primary Care Elderly: Collaborative Trial (PROSPECT) (Unützer et al., 2002, 2006; Alexopoulos et al., 2009). Both IMPACT and PROSPECT utilized randomized control trials, assigning older adults to the intervention program (IMPACT) or assigning primary care practices to provide the intervention or usual care (PROSPECT). IMPACT and PROSPECT employed a care manager to schedule therapy appointments and offer house calls. In IMPACT’s study, participants saw a statistically significant decrease in depressive symptoms from baseline when compared to the control group. PROSPECT saw similar results, with participants seeing a statistically significant decrease in suicide ideation when compared to the control group.

Resources from SafeSide Prevention, Kognito, the American Association of Suicidology (AAS), and Question, Persuade, Refer Institute (QPR) were identified in the grey literature as primary care-centric suicide interventions. These organizations offer online trainings designed to prepare primary care providers to screen patients for mental health and SUDs as well as to intervene with patients who are at risk of suicide. At-Risk in Primary Care, the training offered by software company Kognito, uses a simulation-based approach where providers engage in role-play conversations with virtual patients. Recognizing and Responding to Suicide Risk: Essential Skills for Clinicians, facilitated by the AAS, engages providers in case studies and dyadic exercises to adequately recognize and treat at-risk patients. Similar methods are utilized in SafeSide Primary CARE (SafeSide Prevention) and QPR for Physicians, Physician Assistants, Nurse Practitioners, and Others (QPR). These interventions can be used across all adult age groups, although evidence to assess their effectiveness with older adults is limited. Tailoring these existing programs to older adults could prove beneficial considering the lack of programs tailored to older adults.

### 2.2.2 Emergency Department Interventions

Almost one-half of older adults have at least one emergency department visit every year, and the number of mental health-related emergency department visits for older adults is increasing (Betz et al., 2016). However, research into suicide prevention interventions in an emergency department setting is lacking. A database screening of 142,534 patient visits (for any reason) from eight emergency departments over the course of 3 years revealed that older adults were significantly less likely to be offered suicide risk assessments compared to individuals under the age of 60 years (Betz et al., 2016). When tailored to a specific demographic, screening tools have been proven useful at helping providers identify suicide risk and are part of an effective intervention with patient follow-up and treatment (O’Rourke et al., 2022); therefore, it is crucial that older adults experiencing mental health-related emergencies are screened for suicide risk using tailored assessments. Among older adults aged 75 and older who did complete an assessment, only 1.2 percent were identified as at-risk (Betz et al., 2016). This percentage may be partly attributed to conditions impeding the completion of a suicide risk assessment, such as cognitive impairment and acute illness. However, the reported high suicide rates of older adults suggest that emergency department providers may require further training on screening for suicide risk in older adults and that tools currently used to measure risk in emergency departments should be tailored to diagnose this demographic more accurately (Van Orden & Conwell, 2016; Betz et al., 2016).

### 2.2.3 Home-based Interventions

There are a few home-based suicide prevention interventions for non-ambulatory older adults. The Problem Adaption Therapy (PATH) and the Supportive Therapy for Cognitively Impaired Older Adults (ST-CI) interventions are specifically designed to be delivered at home to depressed older adults with cognitive impairment, with the goal of reducing suicide risk (Kiosses et al., 2015). Techniques used in these interventions range from helping individuals develop problem-solving skills and cultivating compensatory strategies to combat functional limitations (PATH) to improving providers’ skills in empathetic listening, understanding, and encouragement (ST-CI).

Social isolation and loneliness are common suicide risk factors among older adults (Armitage & Nellums, 2020). Although not designed to specifically address suicide or suicide ideation, other home-based interventions sponsored by AARP, Administration for Community Living (ACL), Institute on Aging, and Substance Abuse and Mental Health Services Administration (SAMHSA) target social isolation and loneliness in older adults. Connect2Affect (AARP) provides an online assessment for an older adult to use to measure their risk for social isolation and provides resources for practitioners and family members. The Friendship Line (Institute on Aging) is a telephone hotline service available to older adults across the country. Staffed by volunteers trained to counsel older adults, the Friendship Line is a resource for those experiencing chronic loneliness and depression. BE WITH and ASIST (ACL) are phone-based social connection training programs adapted for use by organizations like Area Agencies on Aging and other components of the aging services network.

The interventions and resources identified in our peer-reviewed and grey literature analyses target similar protective factors: supportive therapeutic relationships (IMPACT, PROSPECT), adequate problem-solving skills (PATH), and connectedness (Connect2Affect, Friendship Line, BE WITH).

## 2.3 Barriers to Assessing Older Adults

Through the peer-reviewed and grey literature searches, we identified several obstacles to assessing older adults for suicide risk. Gender-based differences in presentation, unique risk factors, and an overall decrease in screening all impact the rate and effectiveness of mental health diagnoses in older adults, including depression and suicide ideation.

### 2.3.1 Gender Differences

Expressions of suicide ideation can differ by gender. Likewise, an older adult’s willingness to be assessed and to use available resources for treatment can be impacted by the older adult’s gender. Researchers from the IMPACT trial found that older men were significantly less likely than women to be identified as having depression and subsequently referred to the treatment program. Qualitative interviews indicated that older men express their depression atypically, making it more difficult to recognize a problem and refer them to resources (Hinton, et al., 2006). For example, older men expressed core symptoms, such as feeling down and experiencing a lack of interest, less often than older women. In addition, men were more likely to conceal their depression to avoid stigma and feelings of shame often associated with the perception of depression (Hinton et al., 2006). Older women were more likely to utilize social resources and mental health services such as workshops, telephone counseling, and group meetings (Drapeau, Boyer, & Lesage, 2009).

### 2.3.2 Unique Risk Factors

Older adults experience unique stressors including involuntary retirement, social isolation, thwarted belongingness, feelings of being a burden to others, sadness after the loss of a spouse or partner, physical disease, declining health, and SUD (Betz et al., 2016; Lapierre et al., 2011). These risk factors are not well addressed in most suicide screening tools. In the research conducted by Lapierre et al. (2011), none of the suicide prevention programs addressed substance use in older males. However, a retrospective case-control study reported that alcohol dependence was observed in 35 percent of older men who died by suicide and that alcohol use disorder remained an independent predictor of suicide risk (Waern, 2003). Suicide screening tools could be improved by addressing a wider range of such stressors (Lapierre et al., 2011). There are some screening tools for clinical use that do factor in stressors unique to this population. Examples include the Geriatric Suicide Ideation Scale, Geriatric Depression Scale, and the Interpersonal Needs Questionnaire, all of which would better identify suicide risk among older adults. Screening for upstream stressors may also allow for linkage of vulnerable older patients with community resources to mitigate these stressors (Betz et al., 2016).

### 2.3.3 Decreased Screening

Health care providers are prone to under-recognize and under-diagnose depression and self-harm in older adults versus younger patients (Betz et al., 2016). In a study of universal suicide screening in emergency departments, researchers found that the proportion of patients who receive a mental health screening began to decline at age 60. Rates of screening for suicide ideation also decreased significantly with age, as did the prevalence of positive screens among participating older adults. While the explanation for these findings is unclear, Betz and colleagues hypothesized that at least part of the decline could be attributed to the presence of conditions precluding questioning (e.g., dementia, severe confusion) among older adults (Betz et al., 2016). Barriers such as cognitive impairment and acute illness are factors associated with the age-related decrease in screening and identifying older adults who are at risk (Betz et al., 2016; SPRC, 2017). These findings suggest that emergency department staff should be trained to detect suicide risk in and use protocols created specifically for older adults.

## 2.4 Gaps in Literature

We identified several gaps in the literature during our review. The majority of the peer-reviewed literature we identified focused on suicide prevention programs across the globe, with limited specificity for the United States, and lacked evidence-based studies designed for older adults. There are other studies that evaluated the effects of intervention programs on suicide risk factors, but as the authors did not conceive them as means for late-life suicide prevention they were not included in this review or in the review completed by Lapierre (Lapierre et al., 2011). Among the three literature reviews included in this environmental scan, the lack of research focused solely on or explicitly highlighting an older adult population was a common theme. Much more research is needed on suicide prevention within this specific age group, including the different stressors they face, the symptoms they show, and effective prevention programs for older adults. This is particularly important given that older adults are at such high risk of death by suicide.

Furthermore, there is a lack of research on suicide prevention programs for older adults that address social determinants of health, such as rurality, discrimination based on race or ethnicity, and provider availability. Although the grey literature directed us to several programs delivered via telecommunication, there was a lack of peer-reviewed research on the effectiveness of these programs for older adults. More intervention research is needed to understand the impacts of suicide prevention programs delivered via telecommunication, especially given its increase in use during and since the COVID-19 pandemic. Educational protocols may need to be developed in conjunction with program implementation for older adults unfamiliar with technology commonly used for telecommunication. Finally, suicide prevention programs should incorporate any family caregivers of older adults, such as by providing educational opportunities to identify and mitigate suicide risks.