# APPENDIX B TECHNICAL EXPERT PANEL INTERVENTIONS SUMMARY

Exhibit B-1 describes the different available suicide prevention interventions discussed during the TEP.

EXHIBIT B-1 Available Interventions for Suicide Prevention

Intervention Name | Organization | Targeted Population | Intervention Setting | Targeted Risk Factors | Targeted Protective Factors
988 | National Suicide Prevention Lifeline | Anyone in suicidal crisis or emotional distress | Telephone | Social isolation and loneliness | Problem-solving
AmeriCorps Senior | AmeriCorps | Individuals aged 55 and older | Varies depending on volunteer activity | Social isolation and loneliness, feelings of being burdensome | Not assessed
ASIST/BE WITH | LivingWorks Education | Anyone 16 years or older, but majority are health care professionals | 2-day face-to-face workshop | Trains volunteers to recognize signs of suicide risk | Trains volunteers to provide a skilled intervention and develop a safety plan with a person at risk
Care Partners | University of Washington | Older adults with depression | Partnerships with primary care practices, community-based organizations, and families | Not assessed | Improving care for depression received by older adults
Cognitive behavioral therapy for Insomnia | Unspecified | Older adults with insomnia | Primary care | Cognitive behavioral therapy is used to target insomnia, a risk factor for suicide ideation | Problem-solving, coping skills
Connection Planning | University of Rochester | At-risk older adults | Telephone | Perceived burdensomeness and loneliness | Safety plan development
IMPACT | University of Washington | Older adults with depression | Primary care | Close monitoring of depressive symptoms | Building rapport and community with the patient, person-centered treatment
Primary Care Mental Health Integration | VA | Veterans receiving annual primary care visits | Primary care | Embedded mental health specialists screen for depression, SUDs, and suicide risk | Building rapport with veteran and a support system should the veteran want to seek mental health services
Senior Connection | CDC | Older adults with depression | Older adults’ home, telephone | Social isolation and loneliness | Building support system
Stay Connected | University of Washington (within Care Partners program) | Older adults experiencing social isolation and loneliness due to COVID-19 | Telephone | Social isolation and loneliness | Follow-up phone calls to keep older adult engaged