# APPENDIX A ENVIRONMENTAL SCAN INTERVENTIONS SUMMARY

Exhibit A-1 describes the different available suicide prevention interventions identified through the environmental scan.

EXHIBIT A-1 Suicide Prevention Interventions Identified in the Environmental Scan

Intervention | Sponsoring Organization (if applicable) | Setting | Target Audience | Impact on Depression | Impact on Loneliness | Impact on Suicide Ideation
IMPACT | N/A | Primary care | Older adults diagnosed with depression (non-specific) | Significant decrease | Not measured | Not measured
PROSPECT | N/A | Primary care | Older adults diagnosed with major or minor depression | Not measured | Not measured | Major depression: Significant decrease; Minor depression: Insignificant decrease
PATH | N/A | Home | Older adults diagnosed with major depression and cognitive impairment (ranging from mild cognitive impairment to moderate dementia) | Significant decrease when compared to ST-CI | Not measured | Significant decrease
ST-CI | N/A | Home | Older adults diagnosed with depression and cognitive impairment (non-specific) | Insignificant decrease when compared to PATH | Not measured | Significant decrease
Meals on Wheels | Older Americans Act | Home | Older adults in need of meal delivery services | N/A | Significant reduction | N/A
Connect2Affect | AARP Foundation | Online | Older adults at risk of social isolation | N/A | Provides loneliness assessment and community resources | N/A
Friendship Line | Institute on Aging | Telephone | Older adults experiencing loneliness and depression (nonspecific) | Counselors trained to identify depression symptoms in older adults | Provides telephonic wellbeing check-ins | N/A
BE WITH/ASIST | ACL | Telephone | Older adults at risk of social isolation | N/A | N/A | Counselors trained to identify social isolation and suicide risk
Toolkits | SAMHSA, SPRC, AAS | Varied (primary care, senior living communities, universities) | Providers | Trains providers to identify risk factors, depression symptoms, and SUD | N/A | N/A
At-Risk in Primary Care | Kognito | Primary care | Primary care providers | N/A | N/A | Trains providers to identify suicide risk through virtual role-play conversations
SafeSide Primary CARE | SafeSide | Primary care | Primary care providers | N/A | N/A | Provides primary care providers with a framework for responding to suicide risk within the constraints of primary care
QPR | QPR Institute | Provider offices | Physicians, physician assistants, and nurse practitioners | N/A | N/A | Trains providers in using a rapid assessment protocol and identifying suicide risk in patients and colleagues