# REFERENCES

Administration for Community Living (ACL). (2021) ACL Awards Over $85 Million to Support Adult Protective Services Programs. https://acl.gov/news-and-events/announcements/acl-awards-over-85-million-support-adult-protective-services-programs.
Administration for Community Living (ACL). (n.d.). Adult Day Care. Eldercare Locator. Retrieved April 4, 2023, from https://eldercare.acl.gov/public/resources/factsheets/adult_day_care.aspx.
Administration for Community Living (ACL). (2022). Older Americans Act. Retrieved April 4, 2023, from https://acl.gov/about-acl/authorizing-statutes/older-americans-act.
Airgood-Obrycki, W. (2019). The Growing Problem of Older Adult Homelessness. Joint Center for Housing Studies of Harvard University. Retrieved March 10, 2022, from https://www.jchs.harvard.edu/blog/the-growing-problem-of-older-adult-homelessness#:~:text=While%20the%20number%20of%20people,Housing%20America’s%20Older%20Adults%202019.
Aubry, T., Bloch, G., Brcic, V., Saad, A., Magwood, O., Abdalla, T., Alkhateeb, Q., Xie, E., Mathew, C., Hannigan, T., Costello, C., Thavorn, K., Stergiopoulos, V., Tugwell, P., & Pottie, K. (2020). Effectiveness of permanent supportive housing and income assistance interventions for homeless individuals in high-income countries: A systematic review. Lancet Public Health, 5(6), e342–e360. 10.1016/S2468-2667(20)30055-4.32504587
Aurand, A., Emmanuel, D., Threet, D., Rafi, I., & Yentel, D. (2021). The gap: A shortage of affordable homes. National Low Income Housing Coalition. Retrieved January 31, 2022, from https://reports.nlihc.org/sites/default/files/gap/Gap-Report_2021.pdf.
Baggett, T.P., Hwang, S.W., O’Connell, J.J., Porneala, B.C., Stringfellow, E.J., Orav, E.J., Singer, D.E., & Rigotti, N.A. (2013). Mortality among homeless adults in Boston: Shifts in causes of death over a 15-year period. JAMA Internal Medicine, 173(3), 189–195. 10.1001/jamainternmed.2013.1604.23318302
Baggett, T.P., Singer, D.E., Rao, S.R., O’Connell, J.J., Bharel, M., & Rigotti, N.A. (2011). Food insufficiency and health services utilization in a national sample of homeless adults. Journal of General Internal Medicine, 26(6), 627–634. 10.1007/s11606-011-1638-4.21279455
Bamberger, J.D., & Dobbins, S.K. (2015). A research note: Long-term cost effectiveness of placing homeless seniors in permanent supportive housing. Cityscape, 17(2), 269–278. http://www.jstor.org/stable/26326949.
Barrow, S., Rodríguez, G.S., & Córdova, P. (2004). Final Report on the Evaluation of the Closer to Home Initiative. Corporation for Supportive Housing. Retrieved January 31, 2022, from https://www.hudexchange.info/resource/891/closer-to-home-evaluation-of-the-closer-to-home-initiative/.
Benioff Homelessness and Housing Initiative. (2021). Home Safe Interim Evaluation: Key Findings. Retrieved March 31, 2022, from https://homelessness.ucsf.edu/sites/g/files/tkssra5216/f/resources/home_safe_memo.pdf.
Berg-Weger, M., & Morley, J.E. (2020). Loneliness in old age: An unaddressed health problem. Journal of Nutrition, Health & Aging, 24(3), 243–245. 10.1007/s12603-020-1323-6.
Bielenberg, J.E., Futrell, M., Stover, B., & Hagopian, A. (2020). Presence of any medical debt associated with two additional years of homelessness in a Seattle sample. INQUIRY: Journal of Health Care Organization, Provision, & Financing, 57. 10.1177/0046958020923535.
Blancato, R., & Whitmire, M. (2021). The Crucial Role of Federal Nutrition Programs in Promoting Health among Low-Income Older Adults. American Society on Aging. Retrieved January 31, 2022, from https://generations.asaging.org/federal-nutrition-programs-key-older-adults.
Brown, R.T., Kimes, R.V., Guzman, D., & Kushel, M. (2010). Health care access and utilization in older versus younger homeless adults. Journal of Health Care for the Poor and Underserved, 21(3), 1060–1070. 10.1353/hpu.0.0344.20693744
Brown, R.T., Kiely, D.K., Bharel, M., & Mitchell, S.L. (2011). Geriatric syndromes in older homeless adults. Journal of General Internal Medicine, 27(1), 16–22. 10.1007/s11606-011-1848-9.21879368
Brown, R.T., Thomas, M.L., Cutler, D.F., & Hinderlie, M. (2013). Meeting the housing and care needs of older homeless adults: A permanent supportive housing program targeting homeless elders. Seniors Housing & Care Journal, 21(1), 126–135. Retrieved January 31, 2022, from https://www.ncbi.nlm.nih.gov/pmc/articles/PMC3980491/.24729832
Brown, R.T., Miao, Y., Mitchell, S.L., Bharel, M., Patel, M., Ard, K.L., Grande, L.J., Blazey-Martin, D., Floru, D., & Steinman, M.A. (2015). Health outcomes of obtaining housing among older homeless adults. American Journal of Public Health, 105(7), 1482–1488. 10.2105/AJPH.2014.302539.25973822
Brown, R.T., Goodman, L., Guzman, D., Tieu, L., Ponath, C., & Kushel, M.B. (2016). Pathways to homelessness among older homeless adults: Results from the HOPE HOME study. PLOS ONE, 11(5), e0155065. 10.1371/journal.pone.0155065.27163478
Brown, R.T., Hemati, K., Riley, E.D., Lee, C.T., Ponath, C., Tieu, L., Guzman, D., & Kushel, M.B. (2017). Geriatric conditions in a population-based sample of older homeless adults. Gerontologist, gnw011. 10.1093/geront/gnw011.
Burt, M., Aran, L., Douglas, T., Valente, J., Lee, E., & Iwen, B. (1999). Homelessness: Programs and the People They Serve: Findings from the National Survey of Homeless Assistance Providers and Clients. Technical Report. Washington, DC: Urban Institute.
California Department of Aging. (n.d.). Program Narrative & Fact Sheets--Disease Prevention and Health Promotion. California Department of Aging. Retrieved April 4, 2023, from https://www.aging.ca.gov/Providers_and_Partners/Area_Agencies_on_Aging/Disease_Prevention_and_Health_Promotion/Program_Narrative_and_Fact_Sheets/.
Canham, S.L., Custodio, K., Mauboules, C., Good, C., & Bosma, H. (2020). Health and psychosocial needs of older adults who are experiencing homelessness following hospital discharge. Gerontologist, 60(4), 715–724. 10.1093/geront/gnz078.31228238
Center for Housing Policy. (2015). The Impacts of Affordable Housing on Health: A Research Summary. Center for Housing Policy. Retrieved March 10, 2022, from https://nhc.org/wp-content/uploads/2017/03/The-Impacts-of-Affordable-Housing-on-Health-A-Research-Summary.pdf.
Centers for Disease Control and Prevention (CDC), & National Association of Chronic Disease Directors. (2008). The State of Mental Health and Aging in America Issue Brief 1: What Do the Data Tell Us? Atlanta, GA: National Association of Chronic Disease Directors. Retrieved March 10, 2022, from https://www.cdc.gov/aging/pdf/mental_health.pdf.
Centers for Medicare & Medicaid Services (CMS). (2022). Financial Alignment Initiative (FAI). Retrieved March 31, 2022, from https://www.cms.gov/Medicare-Medicaid-Coordination/Medicare-and-Medicaid-Coordination/Medicare-Medicaid-Coordination-Office/FinancialAlignmentInitiative/FinancialModelstoSupportStatesEffortsinCareCoordination.
Cha, A.E., & Cohen, R.A. (2020). Reasons for Being Uninsured among Adults Aged 18-64 in the United States, 2019. NCHS Data Brief, No. 382. Hyattsville, MD: National Center for Health Statistics. Retrieved March 31, 2022, from https://www.cdc.gov/nchs/products/databriefs/db382.htm.
Chan, D.V., Gopal, S., & Helfrich, C.A. (2014). Accessibility patterns and community integration among previously homeless adults: A geographic information systems (GIS) approach. Social Science & Medicine, 120, 142–152. 10.1016/j.socscimed.2014.09.005.25243640
Chekuri, L., Turturro, C.L., Nekkalapudi, M., & Mittal, D. (2016). Racial differences in older homeless adults: Findings in a homeless sample from Little Rock. American Journal of Geriatric Psychiatry, 24(3), S67–S68. 10.1016/j.jagp.2016.01.066.
Chung, T.E., Gozdzik, A., Palma Lazgare, L.I., To, M.J., Aubry, T., Frankish, J., Hwang, S.W., & Stergiopoulos, V. (2018). Housing First for older homeless adults with mental illness: A subgroup analysis of the At Home. International Journal of Geriatric Psychiatry, 33(1), 85–95. 10.1002/gps.4682.28206715
Cohen C.I. (1999). Aging and homelessness. Gerontologist, 39(1), 5–14. 10.1093/geront/39.1.5.10028766
Cohen S. (2004). Social relationships and health. American Psychologist, 59(8), 676–684. 10.1037/0003-066X.59.8.676.15554821
Coleman-Jensen, A., Rabbitt, M.P., Gregory, C.A., & Singh, A. (2016). Household Food Security in the United States in 2016. U.S. Department of Agriculture. Retrieved January 31, 2022, from https://www.ers.usda.gov/webdocs/publications/84973/err-237.pdf.
Congressional Research Service. (2022). Older Americans Act: Overview and Funding. Retrieved from https://sgp.fas.org/crs/misc/R43414.pdf.
Corporation for Supportive Housing (CSH). (2011). Ending Homelessness among Older Adults through Supportive Housing. Retrieved January 31, 2022, from https://www.csh.org/wp-content/uploads/2012/01/Report_EndingHomelessnessAmongOlderAdultsandSeniorsThroughSupportiveHousing_112.pdf.
Costello, A.M. (2021). RE: Opportunities in Medicaid and CHIP to Address Social Determinants of Health (SDOH). Baltimore, MD.
Couch, L.M. (2020). Falling short: Federal housing assistance is failing older adults. Generations Journal, 44(2), 1–8. Retrieved January 31, 2022, from https://generations.asaging.org/federal-housing-assistance-older-adults-failing.
Couch, L.M. (2021). Section 202: Supportive Housing for the Elderly. National Low Income Housing Coalition. Retrieved March 31, 2022, from https://nlihc.org/sites/default/files/AG-2021/04-13_Section-202.pdf.
Crane, M., Byrne, K., Fu, R., Lipmann, B., Mirabelli, F., Rota-Bartelink, A., Ryan, M., Shea, R., Watt, H., Warnes, A.M. (2005). The causes of homelessness in later life: Findings from a 3-nation study. Journals of Gerontology Series B: Psychological Sciences & Social Sciences, 60(3), S152–S159. 10.1093/geronb/60.3.S152.15860792
Culhane, D.P., Metraux, S., & Hadley, T. (2002). Public service reductions associated with placement of homeless persons with severe mental illness in supportive housing. Housing Policy Debate, 13(1), 107–163. 10.1080/10511482.2002.9521437.
Culhane, D.P., Metraux, S., Byrne, T., Stino, M., & Bainbridge, J. (2013). The age structure of contemporary homelessness: Evidence and implications for public policy. Analyses of Social Issues & Public Policy, 13, 1–17. 10.1111/asap.12004.
Culhane, D.P., Byrne, T., Metraux, S., Kuhn, R., Doran, K., Johns, E., & Schretzman, M. (2019). Emerging Crisis of Aged Homelessness. Retrieved January 31, 2022, from https://aisp.upenn.edu/wp-content/uploads/2019/01/Emerging-Crisis-of-Aged-Homelessness-1.pdf.
DeMallie, D.A., North, C.S., & Smith, E.M. (1997). Psychiatric disorders among the homeless: A comparison of older and younger groups. Gerontologist, 37(1), 61–66. 10.1093/geront/37.1.61.9046707
Dickins, K.A., Philpotts, L.L., Flanagan, J., Bartels, S.J., Baggett, T.P., & Looby, S.E. (2021). Physical and behavioral health characteristics of aging homeless women in the United States: An integrative review. Journal of Women’s Health, 30(10), 1493–1507. 10.1089/jwh.2020.8557.
Dietz, T.L. (2009). Drug and alcohol use among homeless older adults: Predictors of reported current and lifetime substance misuse problems in a national sample. Journal of Applied Gerontology, 28(2), 235–255.
DiPietro, B., Artiga, S., & Gates, A. (2014). Early Impacts of the Medicaid Expansion for the Homeless Population. Kaiser Family Foundation. Retrieved May 1, 2023, from https://www.kff.org/uninsured/issue-brief/early-impacts-of-the-medicaid-expansion-for-the-homeless-population/.
Donaldson, L.P., Streeter, C.L., Larkin, H., Briar-Lawson, K., Meyer-Adams, N., Lupfer, K., Elder, J., & Grimshaw, A. (2020). The SOAR Model as an effective mechanism for university--Community partnerships to end homelessness. Journal of Social Work Education, 56(sup1), S99–S110. 10.1080/10437797.2020.1741481.
Dunton, L., & Brown, S. (2019). Rapid Re-housing in 2018: Program Features and Assistance Models. U.S. Department of Housing and Urban Development. Retrieved March 31, 2022, from https://www.huduser.gov/portal/sites/default/files/pdf/RRH-CommunityScanReport.pdf.
Eldercare Directory. (n.d.). Essential Resources for Senior Citizens and Their Caregivers. Retrieved January 31, 2022, from https://www.eldercaredirectory.org/state-resources.htm.
Gabrielian, S., Cordasco, K.M., Finley, E.P., Hoffmann, L.C., Harris, T., Calderon, R.A., Barnard, J.M., Ganz, D.A., & Olmos-Ochoa, T.T. (2022). Engaging stakeholders to inform national implementation of critical time intervention in a program serving homeless-experienced veterans. Frontiers in Psychology, 13, 1009467. 10.3389/fpsyg.2022.1009467.36591052
Garfield, R., & Orgera, K. (2021). The Coverage Gap: Uninsured Poor Adults in States that Do Not Expand Medicaid. Kaiser Family Foundation. Retrieved March 31, 2022, from https://www.kff.org/medicaid/issue-brief/the-coverage-gap-uninsured-poor-adults-in-states-that-do-not-expand-medicaid/.
Garibaldi, B., Conde-Martel, A., & O’Toole, T.P. (2005). Self-reported comorbidities, perceived needs, and sources for usual care for older and younger homeless adults. Journal of General Internal Medicine, 20(8), 726–730. 10.1111/j.1525-1497.2005.0142.x.16050882
Gelberg, L., Linn, L.S., & Mayer-Oakes, S.A. (1990). Differences in health status between older and younger homeless adults. Journal of the American Geriatrics Society, 38(11), 1220–1229. 10.1111/j.1532-5415.1990.tb01503.x.2147193
Goger, A. (2020). For Millions of Low-Income Seniors, Coronavirus is a Food-Security Issue. Brookings. Retrieved March 31, 2022 from https://www.brookings.edu/blog/the-avenue/2020/03/16/for-millions-of-low-income-seniors-coronavirus-is-a-food-security-issue/.
Goldberg, J., Lang, K., & Barrington, V. (2016). How to Prevent and End Homelessness among Older Adults. Justice in Aging. Retrieved January 31, 2022, from https://www.justiceinaging.org/wp-content/uploads/2016/04/Homelessness-Older-Adults.pdf.
Gonyea, J.G., Mills-Dick, K., & Bachman, S.S. (2010). The complexities of elder homelessness, a shifting political landscape and emerging community responses. Journal of Gerontological Social Work, 53(7), 575–590. 10.1080/01634372.2010.510169.20865621
Gordon, R.J., Rosenheck, R.A., Zweig, R.A., & Harpaz-Rotem, I. (2012). Health and social adjustment of homeless older adults with a mental illness. Psychiatric Services, 63(6), 561–568. 10.1176/appi.ps.201100175.22476721
Grenier, A., Barken, R., Sussman, T., Rothwell, D., & Lavoie, J. (2013). Literature Review: Aging and Homelessness. Retrieved March 31, 2022, from https://aginghomelessness.com/wp-content/uploads/2012/10/Literature-Review-Aging-and-Homelessness.pdf.
Greysen, S.R., Allen, R., Lucas, G.I., Wang, E.A., & Rosenthal, M.S. (2012). Understanding transitions in care from hospital to homeless shelter: A mixed-methods, community-based participatory approach. Journal of General Internal Medicine, 27(11), 1484–1491. 10.1007/s11606-012-2117-2.22707359
Gubits, D., Bishop, K., Dunton, L., Wood, M., Albanese, T., Spellman, B., & Khadduri, J. (2018). Understanding Rapid Re-housing: Systematic Review of Rapid Re-housing Outcomes Literature. U.S. Department of Housing and Urban Development. Retrieved March 31, 2022, from https://www.huduser.gov/portal/sites/default/files/pdf/Systematic-Review-of-Rapid-Re-housing.pdf.
Haarstad, C. (2008). Transportation Voucher Programs: Facilitating Mobility in Rural Areas. Employment Transportation Resources. Retrieved January 31, 2022, from http://www.worksupport.com/documents/transportvouchprogmobilrural.pdf.
Hahn, J.A., Kushel, M.B., Bangsberg, D.R., Riley, E., & Moss, A.R. (2006). Brief report: The aging of the homeless population: Fourteen-year trends in San Francisco. Journal of General Internal Medicine, 21(7), 775–778. 10.1111/j.1525-1497.2006.00493.x.16808781
Health Resources and Services Administration (HRSA). (2018). Federally Qualified Health Centers. Retrieved January 31, 2022, from https://www.hrsa.gov/opa/eligibility-and-registration/health-centers/fqhc/index.html.
Health Resources and Services Administration (HRSA). (2020). 2020 Special Populations Funded Programs. Retrieved March 31, 2022, from https://data.hrsa.gov/tools/data-reporting/special-populations.
Hecht, L., & Coyle, B. (2001). Elderly homeless: A comparison of older and younger adult emergency shelter seekers in Bakersfield, California. American Behavioral Scientist, 45(1), 66–79. 10.1177/00027640121957024.
Henwood, B.F., Katz, M.L., & Gilmer, T.P. (2014). Aging in place within permanent supportive housing. International Journal of Geriatric Psychiatry, 30(1), 80–87. 10.1002/gps.4120.24737594
Henwood, B.F., Lahey, J., Rhoades, H., Winetrobe, H., & Wenzel, S.L. (2018). Examining the health status of homeless adults entering permanent supportive housing. Journal of Public Health, 40(2), 415–418. 10.1093/pubmed/fdx069.28633500
Homelessness Policy Research Institute (HPRI). (2019). Older Adults Experiencing Homelessness. Retrieved January 31, 2022, from https://socialinnovation.usc.edu/wp-content/uploads/2019/08/Older-Adults-Literature-Review-Final.pdf.
Homelessness Policy Research Institute (HPRI). (2020). Homelessness and Employment. Retrieved May 1, 2023, from https://socialinnovation.usc.edu/wp-content/uploads/2020/08/Homelessness-and-Employment.pdf.
HUD Exchange. (n.d.). Rapid Re-housing. Retrieved March 31, 2022, from https://files.hudexchange.info/resources/documents/Rapid-Re-Housing-Brief.pdf.
HUD User. (2019). Tenants in LIHTC Units as of December 31, 2019. Retrieved March 31, 2022, from https://www.huduser.gov/portal/Datasets/lihtc/2019-LIHTC-Tenant-Tables.pdf.
Hui, V., & Habib, K.M. (2014). An Investigation of Transport-Related Social Exclusion of the At-Risk Community (Homeless People) in Toronto, Canada. Retrieved March 31, 2022, from https://trid.trb.org/view/1287880.
Hui, V., & Habib, K.N. (2017). Homelessness vis-à-vis Transportation-Induced Social Exclusion: An Econometric Investigation of Travel Behavior of Homeless Individuals in Toronto, Canada. Transportation Research Record, 2665(1), 60–68. 10.3141/2665-07.
Hurstak, E., Johnson, J.K., Tieu, L., Guzman, D., Ponath, C., Lee, C.T., Jamora, C.W., & Kushel, M. (2017). Factors associated with cognitive impairment in a cohort of older homeless adults: Results from the HOPE HOME study. Drug and Alcohol Dependence, 178, 562–570. 10.1016/j.drugalcdep.2017.06.002.28738314
Hwang, S.W., Orav, E.J., O’Connell, J.J., Lebow, J.M., & Brennan, T.A. (1997). Causes of death in homeless adults in Boston. Annals of Internal Medicine, 126(8), 625–628. 10.7326/0003-4819-126-8-199704150-00007.9103130
Hwang, S.W., Colantonio, A., Chiu, S., Tolomiczenko, G., Kiss, A., Cowan, L., Redelmeier, D.A., & Levinson, W. (2008). The effect of traumatic brain injury on the health of homeless people. Canadian Medical Association Journal, 179(8), 779–784. 10.1503/cmaj.080341.18838453
Jain, S.H., Baackes, J., & O’Connell, J.J. (2020). Homeless special needs plans for people experiencing homelessness. JAMA, 323(10), 927. 10.1001/jama.2019.22376.32053152
Joint Center for Housing Studies of Harvard University. (2018). Housing America’s Older Adults. Retrieved January 31, 2022, from https://www.jchs.harvard.edu/housing-americas-older-adults-2018.
Joint Center for Housing Studies of Harvard University. (2019). Housing America’s Older Adults. Retrieved January 4, 2023, from https://www.jchs.harvard.edu/housing-americas-older-adults-2019.
Johnson, R.W., & Favreault, M.M. (2021). Risk of Economic Hardship Among Older Adults. Washington, DC: Office of the Assistant Secretary for Planning and Evaluation, U.S. Department of Health and Human Services. Retrieved January 13, 2023, from https://aspe.hhs.gov/reports/risk-economic-hardship-among-older-adults-issue-brief.
Kaplan, L.M., Vella, L., Cabral, E., Tieu, L., Ponath, C., Guzman, D., & Kushel, M.B. (2019). Unmet mental health and substance use treatment needs among older homeless adults: Results from the HOPE HOME Study. Journal of Community Psychology, 47(8), 1893–1908. 10.1002/jcop.22233.31424102
Kauff, J.F., Clary, E., Lupfer, K.S., & Fischer, P.J. (2016). An evaluation of SOAR: Implementation and outcomes of an effort to improve access to SSI and SSDI. Psychiatric Services, 67(10), 1098–1102. 10.1176/appi.ps.201500247.27133724
Kochera, A. (2006). Developing Appropriate Rental Housing for Low-Income Older Persons: A Survey of Section 202 and LIHTC Property Managers. AARP Public Policy Institute. Retrieved January 31, 2022, from https://assets.aarp.org/rgcenter/consume/dd149_lihtc.pdf.
Kushel, M. (2012). Older homeless adults: Can we do more? Journal of General Internal Medicine, 27(1), 5–6. 10.1007/s11606-011-1925-0.22086754
Kushel, M. (2020). Homelessness among older adults: An emerging crisis. Generations, 44(2). Retrieved January 31, 2022, from https://stg-generations.asaging.org/homelessness-older-adults-poverty-health.
Larimer, M.E., Malone, D.K., Garner, M.D., Atkins, D.C., Burlingham, B., Lonczak, H.S., Tanzer, K., Ginzler, J., Clifasefi, S.L., Hobson, W.G., & Marlatt, G.A. (2009). Health care and public service use and costs before and after provision of housing for chronically homeless persons with severe alcohol problems. JAMA, 301(13), 1349–1357. 10.1001/jama.2009.414.19336710
Lee, C.T., Guzman, D., Ponath, C., Tieu, L., Riley, E., & Kushel, M. (2016). Residential patterns in older homeless adults: Results of a cluster analysis. Social Science & Medicine, 153, 131–140. 10.1016/j.socscimed.2016.02.004.26896877
Lee, K., Murphy, E.R., Cassidy, J., Chen, Z., and Rhee, T.G. (2020). Impacts of health insurance on older adults with histories of homelessness. Journal of Social Distress & Homelessness. 10.1080/10530789.2020.1819051.
Levin, M., Kauff, J., Negoita, M., Dragoset, L., Goger, A., Baxter, C., Paprocki, A., Makowsky, L., Gutierrez, I., Brown, E., & Sarver, M. (2020). Evaluation of Alternatives to Improve Elderly Access to SNAP. USDA Food and Nutrition Service. Retrieved January 31, 2022, from https://www.fns.usda.gov/snap/evaluation-alternatives-improve-elderly-access-supplemental-nutrition-assistance-program.
Lewin Group. (2011). Design of a Demonstration of Coordinated Housing, Health and Long-Term Care Services and Supports for Low-Income Older Adults. Washington, DC: Office of the Assistant Secretary for Planning and Evaluation, U.S. Department of Health and Human Services. Retrieved April 1, 2022, from https://aspe.hhs.gov/reports/design-demonstration-coordinated-housing-health-long-term-care-services-supports-low-income-older-0.
Li, Z., & Dalaker, J. (2021). Poverty Among the Population Aged 65 and Older. Congressional Research Service. Retrieved March 31, 2022, from https://sgp.fas.org/crs/misc/R45791.pdf.
Libson, N. (2005). The sad state of affordable housing for older people. Generations: Journal of the American Society on Aging, 29(4), 9–15. https://www.jstor.org/stable/26555401.
Lipton, F.R., Siegel, C., Hannigan, A., Samuels, J., & Baker, S. (2000). Tenure in supportive housing for homeless persons with severe mental illness. Psychiatric Services, 51(4), 479–486. 10.1176/appi.ps.51.4.479.10737823
Lowder, E.M., Desmarais, S.L., Neupert, S.D., & Truelove, M.A. (2017). SSI/SSDI Outreach, Access, and Recovery (SOAR): Disability application outcomes among homeless adults. Psychiatric Services, 68(11), 1189–1192. 10.1176/appi.ps.201600568.28760095
Liu, P.-J., & Delagrammatikas, L. (2021). Adult protective service’s role in addressing older and dependent adult abuse in the age of COVID. Frontiers in Public Health, 9. 10.3389/fpubh.2021.659640.
Martinez, T.E., & Burt, M.R. (2006). Impact of permanent supportive housing on the use of acute care health services by homeless adults. Psychiatric Services, 57(7), 992–999. 10.1176/ps.2006.57.7.992.16816284
McDonald, L., Donahue, P., Janes, J., & Cleghorn, L. (2006). In from the Streets: The Health and Well-being of Formerly Homeless Older Adults. National Research Program of the National Homelessness Initiative. 10.13140/RG.2.1.4680.2647.
Medicaid.gov. (n.d.). Program of All-Inclusive Care for the Elderly. Retrieved March 31, 2022, from https://www.medicaid.gov/medicaid/long-term-services-supports/program-all-inclusive-care-elderly/index.html.
Medicare.gov. (n.d.). Medicare Savings Programs. Retrieved August 29, 2022, from https://www.medicare.gov/basics/costs/help/medicare-savings-programs#collapse-2624.
Meret-Hanke, L.A. (2011). Effects of the program of all-inclusive care for the elderly on hospital use. Gerontologist, 51(6), 774–785. 10.1093/geront/gnr040.21737398
Metraux, S., Marcus, S.C., & Culhane, D.P. (2003). The New York-New York Housing Initiative and use of public shelters by persons with severe mental illness. Psychiatric Services, 54(1), 67–71. 10.1176/appi.ps.54.1.67.12509669
Metraux, S., Eng, N., Bainbridge, J., & Culhane, D.P. (2011). The impact of shelter use and housing placement on mortality hazard for unaccompanied adults and adults in family households entering New York City Shelters: 1990-2002. Journal of Urban Health, 88(6), 1091–1104. 10.1007/s11524-011-9602-5.21809153
Moses, J. (2019). Building a Conversation: Aged Homelessness on the Rise. National Alliance to End Homelessness. Retrieved January 31, 2022, from https://endhomelessness.org/blog/building-a-conversation-aged-homelessness-on-the-rise/.
Murphy, E.R. (2019). Transportation and homelessness: A systematic review. Journal of Social Distress & the Homeless, 28(2), 96–105. 10.1080/10530789.2019.1582202.
National Adult Protective Services Association. (n.d.). Getting to Know Adult Protective Services. Retrieved March 6, 2023, from https://www.napsa-now.org/.
National Adult Protective Services Resource Center (NAPSRC). (n.d.). Adult Protective Services, What You Must Know. National Center on Elder Abuse. Retrieved March 6, 2023, from https://ncea.acl.gov/NCEA/media/publications/APS-Fact-Sheet.pdf.
National Alliance to End Homelessness (NAEH). (2021). Permanent Supportive Housing. Retrieved January 31, 2022, from https://endhomelessness.org/ending-homelessness/solutions/permanent-supportive-housing/.
National Association of Area Agencies on Aging (n4a). (n.d. a). Housing Options for Older Adults: A Guide for Making Housing Decisions. Retrieved January 31, 2022, from https://www.usaging.org/files/HousingOptions.pdf.
National Association of Area Agencies on Aging (n4a). (n.d. b). Housing and Homelessness: Services and Partnerships to Address a Growing Issue. Retrieved December 22, 2022, from https://www.usaging.org/Files/Housing%20and%20Homelessness%20-%20Services%20and%20Partnerships%20to%20Address%20a%20Growing%20Issue.pdf.
National Association of Nutrition and Aging Services Programs (NANASP). (2021). NANASP COVID-19 Relief and Vaccine Survey--January 2021. Retrieved January 31, 2022, from https://www.nanasp.org/sites/default/files/documents/Data_Q3_210222.pdf.
National Coalition for the Homeless. (2009). Homelessness among Elderly Persons. Retrieved March 10, 2022, from https://www.nationalhomeless.org/factsheets/Elderly.pdf.
National Council on Aging (NCOA). (2022). How to Make It Easier for Older Adults to Get Energy and Utility Assistance. Retrieved March 31, 2022, from https://www.ncoa.org/article/how-to-make-it-easier-for-older-adults-to-get-energy-and-utility-assistance.
Niño, M.D., Loya, M.A., & Cuevas, M. (2009). Who are the chronically homeless? Social characteristics and risk factors associated with chronic homelessness. Journal of Social Distress & the Homeless, 19, 41–65. Retrieved March 31, 2022, from https://www.semanticscholar.org/paper/Who-are-the-Chronically-Homeless-Social-and-Risk-Ni%C3%B1o-Loya/9be479666f4e9c87cd1ea6609fca01a8aca81984.
North, C.S., Wohlford, S.E., Dean, D.J., Black, M., Balfour, M.E., Petrovich, J.C., Downs, D.L., & Pollio, D.E. (2017). A pilot study using mixed GPS/narrative interview methods to understand geospatial behavior in homeless populations. Community Mental Health Journal, 53(6), 661–671. 10.1007/s10597-016-0057-8.27807686
Novak, M. (2018). Issues on Aging. New York, NY: Taylor & Francis Group. 10.4324/9781315445366.
Nye, E., Lamont, H., & Anderson, L. (2022) Federal Efforts to Address Racial and Ethnic Disparities in Alzheimer’s Disease and Related Dementias (Issue Brief). Washington, DC: Office of the Assistant Secretary for Planning and Evaluation, U.S. Department of Health and Human Services. https://aspe.hhs.gov/reports/federal-efforts-address-adrd-disparities.
Office of Governor Gavin Newsom. (2022). California Expands Medi-Cal to All Eligible Adults 50 Years of Age and Older. CA.gov. Retrieved March 21, 2023, from https://www.gov.ca.gov/2022/04/29/california-expands-medi-cal-to-all-eligible-adults-50-years-of-age-and-older/.
Parpouchi, M., Moniruzzaman, A., Russolillo, A., & Somers, J.M. (2016). Food insecurity among homeless adults with mental illness. PLOS ONE, 11(7), e0159334. 10.1371/journal.pone.0159334.27437937
Patanwala, M., Tieu, L., Ponath, C., Guzman, D., Ritchie, C.S., & Kushel, M. (2018). Physical, psychological, social, and existential symptoms in older homeless-experienced adults: An observational study of the HOPE HOME cohort. Journal of General Internal Medicine, 33(5), 635–643. 10.1007/s11606-017-4229-1.29185174
Perl, L., & Bagalman, E. (2015). Chronic Homelessness: Background, Research, and Outcomes. Congressional Research Service. Retrieved January 31, 2022, from https://sgp.fas.org/crs/misc/R44302.pdf.
Perret, Y.M. (2021). Homelessness and Social Security. Social Security Matters. Retrieved March 31, 2022, from https://blog.ssa.gov/homelessness-and-social-security/.
Prunhuber, P. (2021). Do You Think Older Renters on a Fixed Income Can’t Get Help with Back Rent? Think Again! Justice in Aging. Retrieved March 31, 2022, from https://justiceinaging.org/wp-content/uploads/2021/09/Older-Renters-Can-Get-Help-with-Back-Rent-Utilities.pdf.
Prunhuber, P. & Kwok, V., (2021). Low-Income Older Adults Face Unaffordable Rents, Driving Housing Instability and Homelessness. Justice in Aging. Retrieved March 10, 2022, from https://justiceinaging.org/wp-content/uploads/2021/02/Older-Adults-Rental-Housing-Burdens.pdf.
Public and Affordable Housing Research Corporation (PAHRC). (2020). 2020 Housing Impact Report: Seniors. Retrieved March 31, 2022, from http://www.pahrc.org/wp-content/uploads/2020/04/Spring2020HIR_Seniors-1.pdf.
Ramsey-Klawsnik, H. (2018). Understanding and Working with Adult Protective Services (APS). National Adult Protective Services Association & National Center on Elder Abuse. http://eldermistreatment.usc.edu/wp-content/uploads/2018/05/Understanding-and-Working-with-APS_May2018.pdf.
Raven, M.C., Tieu, L., Lee, C.T., Ponath, C., Guzman, D., & Kushel, M. (2017). Emergency department use in a cohort of older homeless adults: Results from the HOPE HOME Study. Academic Emergency Medicine, 24(1), 63–74. 10.1111/acem.13070.27520382
Ravensbergen, L., Van Liefferinge, M., Isabella, J., Merrina, Z., & El-Geneidy, A. (2022). Accessibility by public transport for older adults: A systematic review. Journal of Transport Geography, 103, 103408. 10.1016/j.jtrangeo.2022.103408.
Robaina, K.A., & Martin, K.S. (2013). Food insecurity, poor diet quality, and obesity among food pantry participants in Hartford, CT. Journal of Nutrition Education & Behavior, 45(2), 159–164. 10.1016/j.jneb.2012.07.001.23219294
Sard, B. (2018). Housing Choice Voucher Program: Oversight and Review of Legislative Proposals. Center on Budget and Policy Priorities. Retrieved January 31, 2022, from https://www.cbpp.org/research/housing/housing-choice-voucher-program-oversight-and-review-of-legislative-proposals.
Schaak, G., Sloane, L., Arienti, F., & Zovistoski, A. (2017). Priced Out: The Housing Crisis for People with Disabilities. Technical Assistance Collaborative, Inc., Consortium for Citizens with Disabilities Housing Task Force. Retrieved from https://www.tacinc.org/wp-content/uploads/2020/04/priced-out-in-2016.pdf.
Schinka, J.A., Schinka, K.C., Casey, R.J., Kasprow, W., & Bossarte, R.M. (2012). Suicidal behavior in a national sample of older homeless veterans. American Journal of Public Health, 102(S1), S147–S153. 10.2105/AJPH.2011.300436.22390590
Schinka, J.A., Curtiss, G., Leventhal, K., Bossarte, R.M., Lapcevic, W., & Casey, R. (2017). Predictors of mortality in older homeless veterans. Journals of Gerontology: Series B, 72(6), 1103–1109. 10.1093/geronb/gbw042.
Schinka, J.A., & Byrne, T. (2018). Aging and Mortality in Homeless Veterans: Nine Questions. Retrieved from https://www.va.gov/HOMELESS/nchav/docs/Schinka_Byrne_AgingLifeExpectancyHomelessVeterans_Sept2018_508.pdf.
Segelman, M., Szydlowski, J., Kinosian, B., McNabney, M., Raziano, D.B., Eng, C., van Reenen, C., & Temkin-Greener, H. (2014). Hospitalizations in the Program of All-Inclusive Care for the Elderly. Journal of the American Geriatrics Society, 62(2), 320–324. 10.1111/jgs.12637.24417503
SeniorNavigator. (n.d.). Special Concerns for the Elderly Who are Homeless. Retrieved March 31, 2022, from https://seniornavigator.org/article/12426/special-concerns-elderly-who-are-homeless.
Sermons, M.W., & Henry, M. (2010). Demographics of homelessness series: The rising elderly population. Homelessness Research Institute. Retrieved January 31, 2022, from https://endhomelessness.org/resource/the-rising-elderly-population/.
Sharma, A. (2019). Santa Monica to subsidize rent for hundreds of seniors. LAist. https://laist.com/news/santa-monica-senior-rental-housing-subsidies.
Shinn, M., Gottlieb, J., Wett, J.L., Bahl, A., Cohen, A., & Baron Ellis, D. (2007). Predictors of homelessness among older adults in New York City: Disability, economic, human and social capital and stressful events. Journal of Health Psychology, 12(5), 696–708. 10.1177/1359105307080581.17855456
Siegler, E.L., Lama, S.D., Knight, M.G., Laureano, E., & Reid, M.C. (2015). Community-based supports and services for older adults: A primer for clinicians. Journal of Geriatrics, 2015(678625). 10.1155/2015/678625.
Spinelli, M.A., Ponath, C., Tieu, L., Hurstak, E.E., Guzman, D., & Kushel, M. (2017). Factors associated with substance use in older homeless adults: Results from the HOPE HOME study. Substance Abuse, 38(1), 88–94. 10.1080/08897077.2016.1264534.27897965
Stone, C., & Chen, W. (2014). Introduction to Unemployment Insurance. Center on Budget and Policy Priorities. Retrieved May 1, 2023, from https://www.cbpp.org/research/introduction-to-unemployment-insurance.
Substance Abuse and Mental Health Services Administration (SAMHSA). (n.d.). Programs. Retrieved April 4, 2023, from https://www.samhsa.gov/programs.
Supplemental Nutrition Assistance Program (SNAP). (n.d.). Addressing Barriers & Challenges--Seniors. Retrieved from https://www.budget.senate.gov/imo/media/doc/Addressing%20Barriers%20and%20Challenges%20-%20Seniors.pdf.
Tolbert, J., & Ammula, M. (2022). 10 Things to Know About the Unwinding of the Medicaid Continuous Enrollment Requirement. Kaiser Family Foundation. https://www.kff.org/medicaid/issue-brief/10-things-to-know-about-the-unwinding-of-the-medicaid-continuous-enrollment-requirement/.
Tompsett, C.J., Fowler, P.J., & Toro, P.A. (2009). Age differences among homeless individuals: Adolescence through adulthood. Journal of Prevention & Intervention in the Community, 37(2), 86–99. 10.1080/10852350902735551.19363770
Tong, M., Tieu, L., Lee, C.T., Ponath, C., Guzman, D., & Kushel, M. (2018). Factors associated with food insecurity among older homeless adults: Results from the HOPE HOME study. Journal of Public Health, 41(2), 240–249. 10.1093/pubmed/fdy063.
Tsemberis, S., Gulcur, L., & Nakae, M. (2004). Housing First, consumer choice, and harm reduction for homeless individuals with a dual diagnosis. American Journal of Public Health, 94(4), 651–656. 10.2105/AJPH.94.4.651.15054020
Turnbull, J., Muckle, W., & Masters, C. (2007). Homelessness and health. Canadian Medical Association Journal, 177(9), 1065–1066. 10.1503/cmaj.071294.17954899
U.S. Census Bureau. (2021). U.S. Census Bureau QuickFacts: United States. U.S. Census Bureau. Retrieved March 3, 2023, from https://www.census.gov/quickfacts/US.
U.S. Department of Agriculture (USDA). (2021). FNS Launches the Online Purchasing Pilot. Retrieved January 31, 2022, from https://www.fns.usda.gov/snap/online-purchasing-pilot.
U.S. Department of Housing and Urban Development (HUD). (2018). The 2017 Annual Homeless Assessment Report (AHAR) to Congress: PART 2: Estimates of Homelessness in the United States. Retrieved March 31, 2022, from https://www.huduser.gov/portal/sites/default/files/pdf/2017-AHAR-Part-2.pdf.
U.S. Department of Housing and Urban Development (HUD). (2023). 2021 Annual Homeless Assessment Report (AHAR) to Congress, Part 2: Estimates of Homelessness in the United States. Retrieved August 21, 2023, from https://www.huduser.gov/portal/sites/default/files/pdf/2021-AHAR-Part-2.pdf.
U.S. Department of Housing and Urban Development (HUD) (n.d. a). Housing Choice Vouchers Fact Sheet. Retrieved March 31, 2022, from https://www.hud.gov/topics/housing_choice_voucher_program_section_8#hcv01.
U.S. Department of Housing and Urban Development (HUD) (n.d. b). Section 202 Supportive Housing for the Elderly Program. Retrieved March 31, 2022, from https://www.hud.gov/program_offices/housing/mfh/progdesc/eld202.
U.S. Department of the Treasury (USDT). (n.d.). Emergency Rental Assistance Program. Retrieved March 31, 2022, from https://home.treasury.gov/policy-issues/coronavirus/assistance-for-state-local-and-tribal-governments/emergency-rental-assistance-program.
U.S. Interagency Council on Homelessness. (2018). Homelessness in America: Focus on Veterans. Retrieved January 31, 2022, from https://www.usich.gov/resources/uploads/asset_library/Homelessness_in_America._Focus_on_Veterans.pdf.
U.S. Government Accountability Office. (2019). Food Insecurity: Better Information could help Eligible College Students Access Federal Food Assistance Benefits. Retrieved January 31, 2022, from https://www.gao.gov/products/gao-19-95.
Van Dongen, S., Klop, J., Onwuteaka-Philipsen, B., De Veer, A., Francke, A., Slockers, M., Van Laere, I., van der Heide, A., & Rietjens, J. (2019). Advance care planning and palliative care for homeless people in medical respite shelters: A retrospective record review. BMJ Supportive and Palliative Care, 9(Suppl 2). 10.1136/spcare-2019-acpicongressabs.41.
Vespa, J. (2020). Those Who Served: America’s Veterans from World War II to the War on Terror. American Community Survey Report. U.S. Census Bureau. https://www.census.gov/content/dam/Census/library/publications/2020/demo/acs-43.pdf.
Wang, Z.J., Dhanireddy, P., Prince, C., Larsen, M., Schimpf, M., & Pearman, G. (2021). 2021 Survey of Veteran Enrollees’ Health and Use of Health Care: Data Findings Report. Advanced Survey Design, LLC. https://www.va.gov/VHASTRATEGY/SOE2021/2021_Enrollee_Data_Findings_Report-508_Compliant.pdf.
Watson, D.P., George, C., & Walker, C. (2008). “Falling through the cracks”: Health care needs of the older homeless population and their implications. Jacobs Kronenfeld, J. (Ed.) In Care for Major Health Problems and Population Health Concerns: Impacts on Patients, Providers and Policy (Research in the Sociology of Health Care, 26), Emerald Group Publishing Limited, Bingley, pp. 187–204. 10.1016/S0275-4959(08)26009-6.
Winetrobe, H., Wenzel, S., Rhoades, H., Henwood, B., Rice, E., & Harris, T. (2017). Differences in health and social support between homeless men and women entering permanent supportive housing. Women’s Health Issues: Official Publication of the Jacobs Institute of Women’s Health, 27(3), 286–293. 10.1016/j.whi.2016.12.011.
Xu, J., Murphy, S.L., Kochanek, K.D., & Arias, E. (2020). Mortality in the United States, 2018. National Center for Health Statistics. Retrieved January 31, 2022, from https://www.cdc.gov/nchs/data/databriefs/db355-h.pdf.
Ye, V.M., Caplan, R.J., Consiglio-Ward, L., & Ellison, J.M. (2019). Health care needs of homeless older adults: Examining the needs of a senior center cohort. Delaware Journal of Public Health, 5(5), 74–80. https://pubmed.ncbi.nlm.nih.gov/34467082/.
Ziliak, J.P., & Gunderson, C. (2020). The State of Senior Hunger in America in 2018. Feeding America. Retrieved January 31, 2022, from https://hungerandhealth.feedingamerica.org/wp-content/uploads/2020/05/2020-The-State-of-Senior-Hunger-in-2018.pdf.