# ACRONYMS

The following acronyms are mentioned in this report.

ACL: HHS Administration for Community Living
ADL: Activity of Daily Living
APS: Adult Protective Services
CAPABLE: Community Aging in Place--Advancing Better Living for Elders
CARES Act: Coronavirus Aid, Relief, and Economic Security Act
CCBHC: Certified Community Behavioral Health Clinic
CDC: HHS Centers for Disease Control and Prevention
CMS: HHS Centers for Medicare & Medicaid Services
CoC: Continuum of Care
COVID-19: Novel Coronavirus
CSH: Corporation for Supportive Housing
DoL: U.S. Department of Labor
ERA: USDT Emergency Rental Assistance
FFS: Fee-For-Service
FQHC: Federally Qualified Health Center
HCBS: Home and Community-Based Services
HHS: U.S. Department of Health and Human Services
HIPAA: Health Insurance Portability and Accountability Act
HOPE HOME: Health Outcomes in People Experiencing Homelessness in Older Middle Age
HPRI: Homelessness Policy Research Institute
HRSA: HHS Health Resources and Services Administration
HUD: U.S. Department of Housing and Urban Development
LGBTQ+: Lesbian, Gay, Bisexual, Transgender, Queer or Questioning, Intersex, Asexual, and More
LIHEAP: HHS Low-Income Home Energy Assistance Program
LIHTC: Low-Income Housing Tax Credit
n.d.: not dated
n4a: National Association of Area Agencies on Aging
NAEH: National Alliance to End Homelessness
NANASP: National Association of Nutrition and Aging Services Programs
NAPSRC: National Adult Protective Services Resource Center
NCOA: National Council on Aging
OAA: Older Americans Act
PACE: Program of All-inclusive Care for the Elderly
PAHRC: Public and Affordable Housing Research Corporation
SAMHSA: HHS Substance Abuse and Mental Health Services Administration
SNAP: Supplemental Nutrition Assistance Program
SNP: Special Needs Plan
SOAR: SSI/SSDI Outreach, Access, and Recovery
SSDI: Social Security Disability Insurance
SSI: Supplemental Security Income
USDA: U.S. Department of Agriculture
USDT: U.S. Department of the Treasury
VA: U.S Department of Veterans Affairs
VHA: Veterans Health Administration