# Acknowledgments

The authors would like to acknowledge the contributions of their colleagues, Ilene Rosin, for assistance with data collection, and Dr. Andreea Balan-Cohen, Dr. Cindy Gruman, and Dr. Beth Rabinovich for review of this report. We would also like to thank our project officers at the U.S. Department of Health and Human Services, Office of the Assistant Secretary for Planning and Evaluation, Lauren Anderson, Emma Nye, and Emily Rosenoff for providing us guidance and support throughout the project.

We also thank the subject matter experts and service providers we interviewed for this project for graciously providing us their time and knowledge. Most importantly, we are grateful to the individuals with lived experience of homelessness in older adulthood who shared with us their experiences and recommendations.