# Executive Summary

The number of older adults at risk of and currently experiencing homelessness has increased rapidly in recent years, a trend that is projected to continue and further accelerate (Culhane et al., 2013; Culhane et al., 2019). Older adults at risk of or experiencing homelessness have unique needs compared to other populations experiencing homelessness. As a first step in understanding how to address the needs of this population, the U.S. Department of Health and Human Services’ (HHS) Office of the Assistant Secretary for Planning and Evaluation contracted with Westat to conduct a study of what is known about older adults experiencing homelessness, including an examination of the size, characteristics, and needs of this vulnerable population and the services, housing, and supports needed and available to serve them. The study included an environmental scan of published research, evaluations, and white papers as well as discussions with subject matter experts, housing and service providers, and people with lived experience of homelessness as older adults.

This report provides a roadmap for understanding the population of older adults at risk of or experiencing homelessness and what services and supports are available to serve them. Using an equity lens, we examine these topics with attention to what is known about racial and ethnic groups disproportionately impacted by homelessness. We highlight the challenges older adults face in accessing the assistance available; innovative practices, especially those implemented during the Novel Coronavirus (COVID-19) pandemic, that could ease these challenges; and remaining gaps that need to be filled to effectively tackle the problem. We end with recommendations to better identify and serve older adults at risk of or experiencing homelessness.

## POPULATION OF OLDER ADULTS EXPERIENCING HOMELESSNESS

Older adults are the fastest-growing age group of those experiencing homelessness, composing nearly half of the homeless population (Kushel, 2022) and their numbers are estimated to triple by 2030 (Culhane et al., 2019). Older adults are especially vulnerable to homelessness as many live on fixed incomes insufficient to cover all their expenses, especially housing expenses (Sermons & Henry, 2010). Half of renters ages 50 and older pay more than 30 percent of their income on housing (Joint Center for Housing Studies, 2018).

Two trends in the growth of homelessness among older adults are apparent: aging of those who first experienced homelessness earlier in life and continue to experience homelessness as older adults and, increasingly, people experiencing homelessness for the first time in older age. The first group represents a cohort effect: individuals born in the second half of the post-World War II baby boom (1954-1963) who throughout their lives have had an elevated risk of homelessness due to limited employment opportunities, coupled with mental health and substance use disorders. The second group of older adults are experiencing homelessness for the first time after age 50 after having lived relatively stable lives including long periods of employment and residential stability. For this group, homelessness is often preceded by stressful life events, such as the death of a spouse or partner, divorce, loss of work, eviction, or the onset of health problems, coupled with limited or fixed incomes (Cohen, 2004; Crane et al., 2005).

## CHARACTERISTICS OF OLDER ADULTS EXPERIENCING HOMELESSNESS

Older adults with earlier experiences of homelessness have had increased vulnerabilities throughout their lives, including more adverse childhood experiences, more mental health conditions, greater alcohol and drug use, higher rates of incarceration, and more underemployment than those with later entry into homelessness (Brown et al., 2016). In addition, this group has spent more time homeless both overall and in their current episodes than those individuals whose first homelessness occurred in older age (Brown et al., 2016).

The few studies that have examined the racial and ethnic composition of older adults experiencing homelessness are limited in their generalizability due to having small samples drawn from limited geographic regions. Despite this limitation, their findings are consistent with national level data in that the percentage of African Americans who are experiencing homelessness is disproportionately large compared to the overall percentage of African American older adults (HUD, 2023; Moses, 2019).

## SERVICE NEEDS OF OLDER ADULTS EXPERIENCING HOMELESSNESS

Compared to their housed counterparts, older adults experiencing homelessness have higher rates of health service utilization and more health and health-related concerns, including:

- Significantly shorter life spans (Metraux et al., 2011; Schinka & Byrne, 2018; Brown et al., 2016; Kushel 2020).
- Higher prevalence and severity of physical and geriatric conditions including memory loss, falls, difficulty performing activities of daily living (ADLs), cognitive impairment, and functional impairments (Brown et al., 2011; Brown et al., 2017; Hahn et al., 2006; Hwang et al., 1997).
- More complex health needs, comparable to housed individuals who are 10-20 years older (Cohen, 1999; Gelberg et al., 1990; Homelessness Policy Research Institute [HPRI], 2019; Brown et al., 2016).
- Higher rates of mental health and substance use disorders (Brown et al., 2011; CDC, 2008; Spinelli et al., 2017).

“Like my body isn’t so resilient. When I was younger, I, mean, I went everywhere and bounced back. And now it’s harder to get up out of the chair, let alone get up off the sidewalk if you’re sleeping outside.” – Adult currently experiencing homelessness, 59

As such, this population has greater need for health care supports, such as access to medications, durable medical equipment, and assistive technology, as well as assistance with ADLs, compared to their housed counterparts.

Compared to individuals younger than 50 years who are homeless, older adults experiencing homelessness have higher rates of chronic illnesses, geriatric conditions, and cognitive impairments as well as high blood pressure, arthritis, and functional disability (Garibaldi et al., 2005; Gelberg et al., 1990). Among people experiencing homelessness, older adults and younger adults have comparable rates of mental health and substance use disorders (DeMallie et al., 1997; Gelberg et al., 1990; Gordon et al., 2012).

Among older adults experiencing homelessness, older adults who first experienced it earlier in life have more behavioral health needs and service utilization than those who first experienced homelessness after age 50. Differences are most pronounced in rates of current mental health issues, including depressive symptoms, post-traumatic stress disorder, and substance use, as well as hospitalizations for mental health conditions (Brown et al., 2016).

Finally, food insecurity, lack of transportation, and loss of community surface as additional challenges for older adults experiencing homelessness. Older adults experiencing homelessness have rates of food insecurity that are nearly two times higher than estimates among all people living in poverty (Coleman-Jensen et al., 2016; Tong et al., 2018). Lack of transportation poses a particularly significant barrier for older adults, who are more likely to have mobility limitations due to health impairments, including poor eyesight and impaired cognition.

## SYSTEMS AND SERVICES AVAILABLE TO SERVE OLDER ADULTS AT RISK OF OR EXPERIENCING HOMELESSNESS

### Homelessness Assistance

Older adults may face unique challenges accessing homelessness assistance, including limited knowledge about the services available for which they are eligible, heightened anxiety about and lack of trust in working with providers, limited access to technology to complete online applications (National Council on Aging [NCOA], 2022), and difficulty attending scheduled appointments, providing documentation of eligibility, or completing the necessary paperwork (Grenier et al., 2013). As noted by experts, many crisis and interim housing facilities may not be accessible to older adults with mobility challenges and difficulty performing ADLs or these facilities may be unable to provide the kind of supports that older adults need. Although some organizations and municipalities offer programs aimed specifically at older adults, most communities do not provide this type of assistance.

Homelessness assistance includes prevention services, identification, engagement, and assessment services, as well as crisis or interim housing.

### Housing Assistance

Access to housing assistance can be difficult given the current lack of availability and the high and growing demand among low-income older adults. Consequently, large numbers of older adults who are eligible for rental assistance either have a long wait time for assistance or do not end up receiving the assistance (Public and Affordable Housing Research Corporation [PAHRC], 2020), a finding reflected in our discussions with people with lived experience. Experts also noted a lack of residential options with sufficient support to enable older adults to age in place.

Housing assistance includes programs that provide time-limited assistance as well as a wide range of permanent subsidized housing options with and without supportive services. These include permanent supportive housing, permanent subsidies, low-income tax credit housing, and a range of residential and institutional care settings that may provide medical management, support services, and social activities.

### Health Care, Long-Term Care, and Behavioral Health Services

Older adults face a number of challenges receiving the health care they need. Meeting basic needs such as food and housing often takes precedence over seeking treatment for physical and behavioral health needs. Lack of available providers within communities, limited provider capacity, a lack of transportation, and mobility challenges further exacerbate difficulties in obtaining the health care that older adults experiencing homelessness need (Baggett et al., 2011; Canham et al., 2020; Kushel et al., 2012; Lee et al., 2020; Ye et al., 2019).

Health care, long-term care, and behavioral health services, including medications, are available for older adults through a variety of federal and state-funded mechanisms including Medicare, Medicaid, VA benefits (for eligible veterans), and OAA and SAMHSA funded programs.

### Basic Needs Assistance

Older adults experiencing homelessness often have difficulty accessing needed assistance. Individuals without fixed addresses and those with limited access to technology, as well as those with health or behavioral health conditions, may have difficulty establishing eligibility for assistance or completing their applications (Tong et al., 2018). Moreover, all of these basic needs programs may be limited in rural areas.

Assistance for basic needs, such as income, food, transportation, and social engagement are provided through a range of federal, state, private, and non-profit programs.

## INNOVATIVE PROGRAMS TO SERVE OLDER ADULTS EXPERIENCING HOMELESSNESS

Numerous agencies and municipalities are implementing innovative programs to address the specific challenges older adults experiencing homelessness face, including with accessing needed assistance. A sample of the programs is highlighted throughout this report. For example:

- The Native American Disability Law Center in New Mexico and Arizona creates accounts for clients in an online benefits application portal to help individuals apply for energy assistance and other public benefits.
- The Hearth program in Boston, Massachusetts provides outreach to older adults at risk of or experiencing homelessness to apply for, locate, and move into subsidized housing.
- Serving Seniors in San Diego, California provides transitional housing with facilities accessible to people with mobility challenges and supportive services focused on the unique needs of older adults experiencing homelessness.
- The Southern California Clinical and Translational Science Institute in Los Angeles County is pilot testing the integration of the Community Aging in Place--Advancing Better Living for Elders (CAPABLE) program with permanent supportive housing to provide home-based services, such as occupational therapists, nurses, and handypersons, to formerly homeless older adults who experience difficulties with ADLs.
- St. Paul’s Programs of All-Inclusive Care for the Elderly (PACE) program in San Diego, California, provides formerly homeless older adults subsidized housing with wrap-around supportive services, including primary and specialty health services, medication assistance, mental health services, occupational therapy, and dentistry, as well as meals and nutrition counseling, social activities, social services, and transportation assistance.

Moreover, during the COVID-19 pandemic, numerous federal, state, and local agencies provided additional assistance to older adults experiencing homelessness to access shelter, housing, and services through increased funding, policy changes or waivers, and new service delivery models. Many of these innovations may be continued or expanded to better serve vulnerable older adults, especially those who experience homelessness.

Examples of Programs Implemented During the Pandemic

- Expanded eviction prevention resources.
- Placement of people experiencing homelessness into motel rooms.
- Medicare coverage of telehealth services.
- USDA’s SNAP Online Purchasing Pilot.

## ADDRESSING GAPS IN SERVICE DELIVERY AND COORDINATION

The environmental scan and discussions identified a number of critical gaps in housing and service availability, accessibility, delivery, and coordination. The following interventions and policy changes offer strategies to enable providers and policymakers to better meet the housing and support needs of older adults experiencing housing instability and homelessness.

- Identification, outreach, and navigation services particularly targeted to older adults experiencing homelessness who have specific barriers to receiving assistance, such as fears of losing their independence or difficulty understanding eligibility requirements Few non-homelessness providers with whom older adults are connected, such as health clinics and benefits offices (e.g., Supplemental Nutrition Assistance Program [SNAP] offices), routinely screen for risk of homelessness. Older adults experiencing homelessness for the first time may not know what types of assistance are available or where to go to get it. They may also wait too long to request assistance to maintain their housing. Older adults experiencing homelessness need resources and assistance to learn about both the available supports for which they are eligible and the processes of applying for and accessing these supports.
- Increased access to benefits and services to provide a greater number of older adults at risk of or experiencing homelessness the assistance they need to address housing, health, and other challenges. Experts noted that restrictive eligibility criteria such as strict income and/or asset requirements, age or disability requirements, and other restrictions prevent or complicate access to key services for older adults experiencing homelessness.
- Crisis and interim housing tailored to older adults. There is a need for emergency shelter accommodations that include beds that are on the first floor or bottom bunk, 24-hour access to bedrooms and bathrooms, and refrigeration or locked storage for medications and medical supplies, as well as crisis or interim housing accessible to older adults with limited mobility, difficulties with ADLs, and needing assistance with limited health care and medication management.
- Permanent supportive housing tailored to older adults with histories of homelessness. Older adults with histories of homelessness often have greater functional impairments and behavioral health challenges, as well as limited connection to their communities. There is a need for permanent supportive housing with physical accommodations (e.g., wheelchair accessible buildings, grab bars in units) to address these needs as well as access to the types of case management and nursing assistance (e.g., medication management, wound care) that will allow them to age in place.
- Consistent case management assistance to assist older adults with accessing the housing and other supports they need.
- Increased capacity of affordable housing. More permanent supportive housing is needed, as well as a continuum of supports to provide tailored assistance to a diverse population of individuals, ranging from those who may need only shallow rental subsidies to those who need intensive medical management and support services.
- Coordination across systems to address the variety and unique needs of older adults experiencing homelessness. Barriers to coordination include siloed funding streams, varying eligibility criteria, overburdened staff, and data sharing barriers.

## GAPS IN KNOWLEDGE

Gaps in knowledge include a lack of:

- Research around equity in services and outcomes.
- Research on the connection between health and homelessness among older adults.
- Documentation of the types of assistance available to older adults and their respective eligibility criteria and enrollment requirements.
- Additional data on older adults experiencing homelessness.

## POTENTIAL STRATEGIES

Through the information identified in this scan, we offer a number of potential strategies for policymakers and service providers to better identify and serve older adults at risk of or experiencing homelessness. Strategies for policymakers at federal, state, and local levels to consider include:

- Additional prevention resources for older adults at risk of homelessness, including short-term rental assistance, resources to help with property taxes, and assistance with home maintenance costs.
- Assistance with other costs of living, including food, transportation, and other expenses that would allow rent-burdened older adults to meet their needs.
- Additional types of affordable housing assistance, such as shallow subsidies and affordable assisted living.
- Expanded state coverage for home and community-based services (HCBS), such as assistance with medication management and wound care; assistance with ADLs; and home management services, to help support individuals as they age.
- Identification of older adults by HUD as a key sub-population in its Annual Homelessness Assessment Reports to provide more national data on older adults experiencing homelessness.
- Better cross-system coordination, including through shared goals, flexible or blended funding streams, better integrated data, and coordination between the No Wrong Door Initiative with coordinated entry systems.
- Continuation of demonstration projects started during the pandemic, such as the U.S. Department of Agriculture (USDA)’s SNAP Online Purchasing Pilot, that facilitated access to services for older adults with limited mobility as well as flexibilities around Medicaid enrollment and housing vouchers.

Potential strategies for service providers include:

- More proactive identification by service providers, such as health clinics and those participating in the No Wrong Door Initiative, of older adults who are severely rent-burdened or otherwise at risk of homelessness.
- Better documentation of services and supports available in local communities to enable older adults at risk of or experiencing homelessness to know what assistance is available and how they can access it.
- Additional assistance accessing medical equipment, such as eyeglasses and hearing aids, that may be damaged or lost while people experience homelessness.
- Training for case management staff on issues specific to older adults.
- Improved access to income assistance for eligible individuals through programs such as Supplemental Security Income (SSI) and Social Security Disability Insurance (SSDI) Outreach, Access, and Recovery (SOAR) to provide a sustainable source of income for a larger share of older adults experiencing homelessness.