# Section 4 Gaps and Potential Strategies

## ADDRESSING GAPS IN SERVICE DELIVERY AND COORDINATION

The environmental scan and discussions identified a number of critical gaps in housing and service availability, accessibility, delivery, and coordination. The following interventions and policy considerations may help providers and policymakers better meet the housing and support needs of older adults experiencing housing instability and homelessness.

### Identification, Outreach, and Navigation Services

Various interviewees recommended better screening and identification of housing instability among non-homelessness providers with whom older adults are connected, such as health clinics and benefits offices, would help prevent many at risk older adults from becoming homeless. Older adults experiencing homelessness need outreach and navigation that is targeted sensitive to their specific barriers to receiving assistance. Experts and providers noted, in particular, that services are needed to help older adults learn about the available supports that match their eligibility and to navigate the process of applying for and accessing that assistance.

Individuals with lived experience of homelessness echoed this sentiment. Two people who experienced homelessness for the first time as older adults reported that they did not know who to turn to for assistance or what assistance was available. Although most individuals reported being connected to a case manager who helped them figure out where to go, they reported primarily learning about the assistance available through other people on the street.

“They should have more people that will go down there to try to help them to get off the damn street because once you’re on the street, it is so hard to keep it together and get off the street.” – Male, 57

### Increased Access to Benefits and Services

Experts and providers noted that restrictive eligibility criteria also prevent or complicate access to key services for this population. Some criteria, such as for Medicaid long-term care (including HCBS), have strict income and/or asset requirements that require recipients to exhaust nearly all savings before receiving coverage. The asset limits for Medicaid eligibility for these services are typically no more than $2,000 for an individual or $3,000 for couple.^9^ Other programs, such as SSI, have strict age and/or disability criteria, limiting services to people over age 60 or 62. Veterans who have been dishonorably discharged are ineligible for VA assistance. Permanent supportive housing programs are often limited to those who have experienced chronic homelessness and are thus unavailable to older adults who are at risk but do not have histories of homelessness. Undocumented individuals are ineligible for most types of federally-funded assistance.^10^ Experts noted that overall, older adults experiencing homelessness are at increased risk of morbidity and mortality compared to the housed population and need access to these benefits and services.

### Crisis and Interim Housing Tailored for Older Adults

Experts and providers reported a need for homelessness assistance that was tailored to older adults’ unique challenges. For example, emergency shelter accommodations should include beds that are on the first floor or bottom bunk, 24-hour access to bedrooms and bathrooms, and refrigeration or locked storage for medications and medical supplies. Additionally, they noted, providers who serve older adults at risk of or experiencing homelessness must be sensitive to the emotional needs of older adults, who may be struggling with shame and sadness due to needing assistance or being disconnected from their families.

### Permanent Supportive Housing Tailored to Older Adults with Histories of Homelessness

Older adults with histories of homelessness often have additional challenges moving into permanent supportive housing than older adults without such histories. These include greater functional impairments and behavioral health challenges, as well as limited connection to their communities. There is a need for additional permanent supportive housing specifically tailored to these older adults with physical accommodations (e.g., wheelchair accessible buildings, grab bars in units) to address these needs as well as access to the types of case management and nursing assistance (e.g., medication management, wound care) that will allow them to age in place.

### Consistent Case Management Assistance

The majority of older adults with lived experience with whom we spoke indicated that case management help was critical to getting the assistance they needed. When asked how they knew where to go for assistance, ten of the 14 individuals said they learned about help through their case managers. For those in permanent supportive housing, this case management was, most often, associated with the housing program. People not in housing mentioned that case managers at emergency shelters were also helpful in providing guidance about where to go for help. Four individuals spoke of the difficulties navigating the system when they did not have case managers or when there was case manager turnover, which prevented them from getting the help they needed. Research shows that low wages and a demanding work environment are associated with high rates of case manager and supervisor turnover in many organizations, both of which can disrupt clients’ access to appropriate and timely services (Gabrielian et al., 2022). A current shortage of direct care workers and case managers exacerbates the challenges of system navigation for many older adults.

“I talked with [my case manager] 1 time and now he’s gone for 2 or 3 weeks doing something, I don’t know what, and won’t be back.” – Female, 59

### Inadequate Capacity of Affordable Housing

Echoing findings from the research, experts and providers spoke of the need for more affordable housing for older adults at risk or experiencing homelessness. In particular, they identified a need for more permanent supportive housing as well as other subsidized housing for older adults, including Supportive Housing for the Elderly (Section 202) and Housing Choice Voucher (Section 8) units. For most housing assistance programs, such as Section 8 vouchers, waitlists can be years long, and once an individual receives a voucher, low housing vacancy rates and landlord bias can effectively prevent people from securing affordable housing.

### Lack of Coordination Across Systems

Across discussions, the most-widely identified issue with serving older adults experiencing homelessness was a lack of coordination across the various systems that serve older adults at risk of or experiencing homelessness. This lack of coordination happens on multiple levels. At a systems level, cross-systems coordination has not been a federal priority, funding streams are often siloed, and eligibility criteria vary. Multiple experts indicated that many programs, for example, may make sense fiscally but run into barriers due to the “wrong pocket problem” such that the money that needs to be spent comes from a different coffer than money that will be saved. For example, greater investments in prevention services or housing stabilization services will likely result in improved health outcomes. Yet, the savings that result from those improvements are unlikely to benefit agencies that provide prevention or housing assistance.

“All the different agencies, they don’t communicate with each other like they should. And, well, a couple of times I’ve got responses from the agencies that I need to recertify and I have sat down and went through all that paperwork and sent it off and I still get the threatening letters.” – Male, 74

Experts and providers noted that it is no one person’s or agency’s job to coordinate across systems and social service agencies are often too understaffed to take this on. Others indicated that most systems are quite complex and use different language and data systems, making it difficult to communicate. Coordination may be further challenged by program requirements that are hard for people experiencing homelessness to meet. For example, some PACE programs serve older adults living in subsidized housing with wrap-around supportive services, including primary and specialty health services, medication assistance, mental health services, occupational therapy, dentistry, as well as meals and nutrition counseling, social activities, social services, and transportation assistance. Although this model has successfully coordinated care for homeless people in a few select locations, such as San Diego, as a Medicare benefit option, it was not originally designed to serve this high-need population. Individuals with long histories of homelessness may have more functional impairments and behavioral health needs than is covered by PACE payment rates.

Finally, many aging, health, and long-term care service systems do not routinely screen for housing instability among their clients and thus service providers are unaware that they need to coordinate with housing and homelessness providers. When they are aware of the coordination that is needed, HIPAA regulations can make it difficult for care providers to communicate about their shared clients. Moreover, distinct data systems across systems make it difficult for providers to track individuals’ service receipt to ensure they are getting the assistance they need.

## GAPS IN KNOWLEDGE

The experts and providers interviewed largely concurred that insufficient research has focused specifically on older adults experiencing homelessness, a small but growing population of people. Those interviewed provided insight into areas they would like to see additional research to inform policy and services moving forward.

### Research on Equity in Services and Outcomes

One key area raised by many individuals with whom we spoke was the need for more research focused on equity in services and outcomes for older adults experiencing homelessness. Racism and language barriers can prevent individuals from accessing the assistance they need, though providers may not understand the extent to which this occurs. Experts pushed for additional research unpacking whether there are differences by race and ethnicity in the types and amount of assistance received by people experiencing homelessness as well as the causes of those differences. One expert also called for research exploring the extent to which older adults who are LGBTQ+ receive the assistance they need.

### Research on the Connection between Health and Homelessness among Older Adults

Another area in which older adults are understudied is the intersection of health and homelessness. Experts noted cognitive impairment in older age may contribute to individuals’ risk of homelessness as they struggle to manage their finances. Yet, interviewees called for more research exploring cognitive decline once individuals become homeless. One expert noted that individuals experiencing sleep deprivation or severe depression, common conditions among those who are homeless, may be misdiagnosed with dementia on health assessments. Another cited preliminary research indicating that cognitive tests for people experiencing homelessness are far more unstable over time than among their housed counterparts and that moving into housing results in improved cognition. Yet more research is needed in this field, including to understand racial-ethnic differences in cognitive decline for people experiencing homelessness (Nye et al., 2022).

### Documentation of Available Assistance

Experts also cited a need for additional documentation of the types of assistance available to older adults at risk of or experiencing homelessness as well as the eligibility criteria and enrollment requirements across systems. This work can guide federal and state policymakers about what help is available, where gaps in assistance exist, and when individuals are most likely to need interventions to help them access and maintain the services they need. This report serves as a starting point to meet this need, yet additional work is needed to document the complex eligibility and enrollment requirements for programs, particularly those that vary by state or municipality. One expert suggested they would like to see a map of all of the moments that a Medicaid-eligible individual could lose or be denied coverage for failing to provide necessary documentation. This exercise, they argued, could inform policy recommendations to simplify the process as well as provide case managers with guidance about the types of assistance needed.

### Additional Data on Older Adults Experiencing Homelessness

Finally, interviewees identified a need for additional data focused on older adults experiencing homelessness. Some experts pointed to state and local municipalities, such as Washington State, Rhode Island, Allegheny County, and Los Angeles County, that have integrated databases that could provide insight into the service needs and experiences of older adults experiencing homelessness across multiple systems. However, federal homelessness data include limited information about older adults, making it hard to identify the size and composition of the population or their service needs.

## POTENTIAL STRATEGIES

Through the information identified in this study, we offer a number of potential strategies for policymakers and service providers to better identify and serve older adults at risk of or experiencing homelessness. Strategies for policymakers to consider include:

- Additional prevention resources. Experts and providers with whom we spoke identified prevention services as both cost-effective and compassionate approaches to serving older adults at risk of homelessness. These services include short-term rental assistance until affordable housing can be located, permanent shallow rental subsidies, resources to help with property taxes, and assistance with home maintenance costs.
- Assistance with other costs of living. With increasing costs of food, transportation, and other expenses, rent-burdened older adults will increasingly struggle to pay for housing. Providing assistance with these other expenses, through established programs such as Meals on Wheels and new programs developed during the pandemic, will allow for additional resources to be allocated towards housing without sacrificing other needs.
- Additional types of affordable housing assistance. Shallow subsidies that provide a small, ongoing amount of rental assistance to older adults on fixed incomes could prevent or end their homelessness. In discussions, many experts and providers spoke of the need for a broader range of affordable housing situations, such as affordable assisted living for older adults who need limited assistance but do not require nursing home-level care.
- Expanded state coverage for HCBS for at risk individuals. HCBS can help support older adults and individuals with disabilities live in the community. Such services include assistance with medication management and wound care; assistance with ADLs; home management services, such as housekeeping and home repairs; transportation to medical appointments as well as other locations such as grocery and clothing stores; opportunities for social engagement; and case management assistance. Strategies might include ensuring that eligible individuals in transitional housing and permanent supportive housing have access to needed personal care to help with ADLs. States can also consider covering housing-related services and supports under their HCBS systems, such as pre-tenancy services for individuals transitioning from homelessness or institutions or assistance with home modifications (Costello, 2021).
- Identification of older adults by HUD as a key population. One limitation to understanding the size and characteristics of the population of older adults experiencing homelessness is the limited data available. Despite older adults comprising a growing share of the population of adults experiencing homelessness, HUD does not designate older adults as a population of focus in its Annual Homelessness Assessment Reports. Thus, no national data are available on the characteristics (e.g., gender, race, ethnicity) or geographic distribution of older adults experiencing homelessness and no data exist on the number of older adults experiencing unsheltered homelessness.
- Better cross-systems coordination. Many interviewees noted that most systems that serve older adults experiencing homelessness do not coordinate with one other. They suggested addressing homelessness among this population through cross-systems coordination needs to be a federal priority and can be fostered through shared goals, flexible or blended funding streams, and better integrated data systems. On a local level, CoCs could work with ACL to ensure that No Wrong Door providers and providers of coordinated entry are well-connected and can easily make referrals between their programs to best meet the needs of older adults experiencing homelessness.
- Continuation of programs started during the pandemic. A number of programs adopted or expanded during the pandemic, such as telemedicine and the USDA’s SNAP Online Purchasing Pilot, provided older adults access to the assistance they needed when they could not leave their homes. A continuation of these programs would increase access to assistance for older adults with mobility limitations due to health impairments, including poor eyesight and poor memory.

Potential strategies for service providers include:

- More proactive identification of older adults at risk of homelessness. Experts and providers both noted that many older adults at risk of homelessness do not reach out for assistance until it is too late to maintain their housing because they do not know where to go for help or they are unwilling to ask for it. While Area Agencies on Aging are increasingly fielding calls on assistance to address housing instability and homelessness, there could be more proactive identification of older adults at risk of losing their housing. Service providers, such as health clinics and those participating in the No Wrong Door Initiative, may be in a good position to implement strategies (such as routine screenings) to identify older adults who are severely rent-burdened or otherwise at risk of homelessness and then work to connect those adults to available services.
- Better documentation of services and supports available in local communities. This documentation of assistance, as well as the eligibility criteria for receipt of assistance, will enable more older adults at risk of or experiencing homelessness to know what assistance is available and how they can access it. This resource must be regularly maintained and easy for people to access, such as through city or county websites, local service providers, and locations older adults frequently visit (e.g., public libraries).
- Additional assistance accessing medical equipment for people experiencing homelessness. Older adults experiencing homelessness face challenges accessing assistive technology, such as eyeglasses and hearing aids, that may be lost or damaged while they are living in places not suitable for human habitation or are moving frequently from shelter to shelter. Homelessness providers could connect with services in their communities to assist older adults with providing or replacing this equipment. In addition, shelter and transitional housing providers should provide accommodations for people with limited mobility such as grab bars and shower safety seats.
- Training for case management staff on issues specific to older adults. With the rate of older adults experiencing homelessness increasing, CoCs should provide training for front-line staff on issues specific to older adults experiencing homelessness. Such training could provide staff with sensitivity to and strategies for addressing feelings of distrust of assistance, concerns about losing their independence, and difficulty using public transportation and remembering scheduled appointments. Training could also address the range of service needs that are more common among older adults experiencing homelessness and list the providers in the community that can help address such needs.
- Improved access to sufficient income assistance for eligible individuals. Programs such as SSI are designed to prevent destitution, premature illness, and death among people who are 65 and older, blind, or disabled. Yet few older adults experiencing homelessness under age 65 receive the benefit, despite having significant health and mental health challenges. More aggressive outreach and enrollment through programs such as SOAR would provide a sustainable source of income for a significant share of older adults experiencing homelessness. In addition, SSI payments are insufficient to support individuals with their living expenses. In 19 states and the District of Columbia, statewide average one-bedroom rents are higher than monthly SSI payments and in the remaining states, monthly rents are equal to 75 percent or more of monthly SSI payments (Schaak et al., 2017).

## CONCLUSION

Older adults at risk of and experiencing homelessness are an especially vulnerable population with a higher prevalence and severity of a number of health and behavioral health challenges than both their housed counterparts and younger adults experiencing homelessness. As the number of older adults experiencing homelessness continues to grow, it is critical to understand their unique set of needs as well as the services and supports that are available and accessible to address them. This environmental scan provides a roadmap for better understanding this population, including older adults’ pathways into homelessness, their characteristics, and service needs. It outlines the range of services and supports available to address those needs across service delivery systems. Finally, it documents the unique challenges older adults experiencing homelessness face in accessing the assistance available and offers a number of potential strategies for better serving this population.

9 California is implementing a new policy that is phasing out this asset limit beginning in July 2022 (Justice in Aging, 2022).

10 Beginning in May 2022, California expanded Medi-CAL access to all individuals who are 50 years or older regardless of immigration status. Under this expansion, all individuals who meet Medi-CAL full-scope eligibility are eligible for primary, specialty, behavioral health, and long-term care as well as in-home supportive services, HCBS, transportation, vision, and hearing aid coverage (Office of Governor Gavin Newsom, 2022).