# Section 3 Systems and Services Available to Serve Older Adults at Risk of or Experiencing Homelessness

Exhibit 3 presents a conceptual systems framework for understanding the different services needed by older adults experiencing homelessness and the service delivery systems that may offer these services. The framework highlights the two subgroups of older adults experiencing homelessness identified through recent studies and the pathways of services, housing, and support likely needed to become stably housed. These two subgroups provide a rubric for understanding the types of assistance older adults experiencing homelessness need, but within the broader acknowledgement that each person has their own unique history and needs.

Exhibit 3 Systems Framework for Addressing Homelessness Among Older Adults

EXHIBIT 3: This framework lays out the unique intervention pathways needed by older adults who first experienced homelessness earlier in life and older adults first experiencing homelessness at age 50 or older. It also illustrates the coordinated set of services needed by all older adults experiencing homelessness and the systems involved in providing those services.

Older individuals who repeatedly experience homelessness often require extensive outreach and emergency shelter before obtaining housing and supports. To achieve long-term stability, many require ongoing case management to help link them to needed health and behavioral health care, income supports, and other services. In contrast, older adults who have not previously experienced homelessness, but have experienced adverse events that threaten their housing stability, tend to need lighter touch or prevention-focused services to regain housing stability. Critical services for this population are those that help identify them before they become homeless so that they may be prevented or diverted from homelessness through various systems’ efforts to connect them to income supports, medical insurance, rental and utility assistance, nutrition assistance, and transportation assistance. For those who need additional housing assistance, shallow subsidies (limited rental assistance for a longer period of time) or temporary subsidies and connections to needed supports may be sufficient to help them get back on their feet (Goldberg et al., 2016; Sermons & Henry, 2010).

We reviewed available information across the systems and sectors shown above for each of the areas of needs older adults at risk of or experiencing homelessness have (e.g., housing, health and long-term care, behavioral health, income and benefits, basic needs). We identified the services, housing, and supports available to low-income older adults and those experiencing homelessness specifically. We paid particular attention to innovations implemented during the COVID-19 pandemic that might be continued or expanded to better serve vulnerable older adults, especially those who experience homelessness. Where documented in the literature, we discuss the challenges service providers and recipients encounter in providing or receiving assistance. Finally, we identify the gaps in services and supports in serving older adults experiencing homelessness.

In this section, we describe the full range of services, housing, and supports available for adults at risk of or experiencing homelessness available across communities. Not all communities have all these types of assistance and those that do may have insufficient capacity to meet the need. In addition, not all are tailored to older adults. We indicate those services that are specifically targeted to older adults or other activities in place to help older adults access or use the service.

## HOMELESSNESS ASSISTANCE

Homelessness assistance programs are available for older adults who are at risk of or experiencing homelessness in communities across the country. HUD is the primary funder of homelessness assistance, which is administered locally through Continuums of Care (CoCs). Many communities also receive state, local, and private funding for homelessness programs. This assistance includes:

- Homelessness prevention.
- Identification, engagement, and assessment of people experiencing homelessness such as outreach programs, drop-in centers, and coordinated entry systems.
- Crisis or interim housing assistance.

### Homelessness Prevention

Services available for older adults at risk of becoming homeless that stabilize their housing situation include energy assistance, home repair programs, and eviction prevention resources. Local government agencies or non-profit organizations typically administer these programs and make them available to all low-income households, not specifically elderly households.

Energy assistance programs help with home energy bills, energy crises, weatherization, and energy-related minor home repairs. These assistance programs are provided through a range of federal, state, and local funding sources including the U.S. Department of Health and Human Services (HHS) Low-Income Home Energy Assistance Program (LIHEAP) and the Low Income Household Water Assistance Program, and the U.S. Department of Energy’s Weatherization Assistance Program.

Home modification and repair assistance programs help older adults address health and safety hazards in and improve accessibility of their homes to reduce the risk of falls and accidents. The USDA’s Section 504 Home Repair program and local Area Agencies on Aging offer such programs. Each program has its own eligibility criteria and application process.

Eviction prevention resources are available for older adults at risk of homelessness. Prior to the COVID-19 pandemic, this assistance typically included financial assistance for 1-2 months’ rent and was available through a range of federal, state, and local public and private sources, including faith-based and non-profit organizations. In response to the financial crisis caused by the COVID-19 pandemic, the U.S. Department of the Treasury’s (USDT’s) Emergency Rental Assistance (ERA) Program provided up to 18 months of rental and utility assistance both for arrears and prospective payments (USDT, n.d.).^3^ Eligibility for eviction prevention through this program was limited to renters with household incomes below 80 percent of the area median income who experienced COVID-related financial hardship and could demonstrate a risk of homelessness or housing instability.

Profile of Prevention Services for Older Adults

In New Mexico and Arizona, the Native American Disability Law Center, a non-profit organization that advocates for the legal rights of Native Americans with disabilities, creates accounts for their clients in an online benefits application portal, including setting up email addresses for those who do not have them. This process helps individuals apply for and track LIHEAP funds, as well as other public benefits.

The Home Safe Program in California was established in 2018 to support the safety and housing stability of individuals involved with Adult Protective Services by providing housing-related assistance using evidence-based practices for homeless assistance and prevention. Home Safe offers a range of strategies to prevent homelessness, including housing-related intensive case management, short-term housing-related financial assistance, deep cleaning to maintain safe housing, eviction prevention, and landlord mediation (Benioff Homelessness & Housing Initiative, 2021).

### Identification, Engagement, and Assessment Programs

Homelessness assistance programs focused on identifying people experiencing homelessness and engaging them in services include street outreach teams, mobile vans, and drop-in centers, among others. Most outreach and engagement programs are not limited to older adults; however, some programs across the country specifically target older adults.

Profile of Outreach Services for Older Adults

Hearth, Inc. in Boston, Massachusetts, funded through both public and private sources, provides outreach to individuals aged 50 years and older who are at risk of or experiencing homelessness. A team of six case managers, supervised by a licensed social worker, visits homeless shelters weekly to identify older adults needing permanent housing. Outreach workers help these older adults apply for, locate, and move into subsidized housing and connect to other necessary services and assistance. The program also employs an “at risk” case manager who works with older adults who are at risk of homelessness, referred through day shelters, medical providers, elder services, and visiting nurse association agencies, among other sources. When at risk elders are identified and enrolled in the program, the case manager helps to stabilize housing by accessing services including tenant counseling, landlord mediation, money management, and eviction prevention (Brown et al., 2013).

### Crisis/Interim Housing Programs

Crisis or interim housing^4^ is short-term assistance designed to address an immediate housing crisis. Assistance includes emergency shelter, motel vouchers, and transitional housing. According to the 2018 Annual Report to the Annual Homeless Assessment Report, approximately, more than 16 percent of people living in sheltered homeless situations were over the age of 55 (HUD, 2020), and the rate is increasing. Limited crisis or interim housing programs are in place specifically for older adults experiencing homelessness.

Profile of Crisis or Interim Housing for Older Adults

One noteworthy program is the Serving Seniors’ Transitional Housing Program in San Diego, California, which provides transitional housing and supportive services for 90-120 days to adults aged 62 and older experiencing homelessness. The program tailors its shelter facilities and services to the specific needs of older adults, including having facilities accessible to people with mobility challenges and case management focused on the unique needs of older adults.

### Challenges with Homelessness Assistance for Older Adults Experiencing Homelessness

Older adults experiencing homelessness may face unique challenges in accessing available homelessness assistance. In discussions, both experts and providers noted that many older adults at risk of homelessness do not reach out for assistance until it is too late because they do not know where to go for help or they are too proud to ask for it. This is particularly true for those experiencing homelessness for the first time who may lack knowledge about the services available in their communities or about their eligibility for assistance. For example, many older renters, particularly those not working prior to the pandemic, may not know they are eligible for eviction prevention through the ERA Program (Prunhuber, 2021). Providers also report that older adults who experience homelessness are sometimes difficult to engage in services due to their belief that participation might result in being “put in a home,” losing their independence or having their money taken from them (Corporation for Supportive Housing [CSH], 2011). Finally, age-related hearing and vision loss may contribute to heightened anxiety and lack of trust.

Those who do know about homelessness assistance may have a hard time accessing it because of poor health or limited mobility (CSH, 2011; SeniorNavigator, n.d.), or they may lack access to technology to complete online applications (NCOA, 2022). Accessibility challenges and difficulty performing ADLs also may make using some assistance, such as emergency shelters, more difficult (Goldberg et al., 2016).

Equipment such as hearing aids and glasses are at risk of being broken or lost in both unsheltered environments and shelters (Kushel, 2012). Shelters closed during the day pose challenges for older adults who need a safe location to rest (SeniorNavigator, n.d.). Features of some shelter environments, such as bunk beds and shared bathing facilities, may be difficult for older adults who have medical conditions and may increase their risk of falls and injury (Goldberg et al., 2016). Walking long distances or waiting in long lines for food and other services can limit access for people with mobility issues (National Coalition for the Homeless, 2009). Finally, limited assistance, such as one-time prevention resources or time-limited rental assistance, may be insufficient to meet the needs of older adults on limited, fixed incomes who also have declining health.

“I broke my glasses, because I kept taking them off and sleeping with them on the street. I had them cobbled together with tape, which never quite fixed them. Eventually, I was given a pair of hand-me-down glasses [by a case manager] that were not my prescription, but it was better than nothing.” – Female, 51

### Expanded Services During the COVID-19 Pandemic

During the COVID-19 pandemic, numerous federal, state, and local agencies provided additional assistance to people experiencing homelessness to access shelter, housing, and needed services. The Coronavirus Aid, Relief, and Economic Security (CARES) Act provided additional funding for states through existing federal programs, including $45 billion for the Federal Emergency Management Agency Disaster Relief Fund, $4 billion for Emergency Solutions Grants, and $5 billion for 11 Community Development Block Grants. Communities could use these funds to secure, rehabilitate, and maintain sites for non-congregate shelters such as dorms, motels, and hotels. In discussions, experts and providers noted that efforts such as California’s Project Roomkey to move older adults experiencing homelessness out of congregate shelters and off of the streets into motel rooms were practical and compassionate approaches. These approaches not only provided people with a safe, stable place to stay but also made it easier for case managers to locate and regularly connect with them.

## HOUSING PROGRAMS AND RESIDENTIAL LONG-TERM CARE OPTIONS

Housing assistance programs range from those that provide time-limited assistance to permanent subsidized options with and without supportive services. Exhibit 4 outlines the types of housing options available. As noted, however, not all options are available in all communities or in the quantity needed. Each housing option is described in more detail below.

Based on their examination of the shelter, hospital, and nursing home use by older adults experiencing homelessness, Culhane and colleagues (2019) argue that the majority of older adults experiencing homelessness have moderate needs that could be met by rapid re-housing, shallow rental subsidies, and rental vouchers with light case management. Older adults who enter homelessness at a later age and have fewer service needs may require more of a “light touch” approach. Service-intensive assistance, such as permanent supportive housing and additional supports like palliative care and long-term care (such as personal care to assist with ADLs), should be reserved for those homeless older adults with the greatest needs (Culhane et al., 2019). Older adults who have experienced chronic or repeated homelessness are more likely to fit within this category of higher need.

Exhibit 4 Types of Housing Assistance Available for Older Adults Experiencing Homelessness

Type of Assistance | Description
Rapid re-housing | Time-limited rental assistance, coupled with housing navigation and case management
Permanent supportive housing | Non-time-limited rental assistance with voluntary supportive services
Subsidized permanent housing | Non-time-limited rental assistance for use in a range of settings, from scattered single-family houses and apartments to high-rise apartments for elderly households
Low-income tax credit properties | Properties with certain percentages of units set aside for low-income households at reduced rents

### Rapid Re-housing Programs

Rapid re-housing, a Housing First^5^ approach, provides access to permanent housing through time-limited rental assistance along with housing navigation to locate and secure an available unit, relocation services, and case management (HUD Exchange, n.d.). First developed on a federal level in 2009 through HUD’s Homelessness Prevention and Rapid Re-housing Program funded under the American Recovery and Revitalization Act, rapid re-housing has continued to expand through federal investments, including investments from HUD, VA, HHS, and the U.S. Department of Labor (DoL). A variety of non-federal investments, including general revenue funds, and state funding (e.g., federal block grant funds, state housing trust funds) have increasingly been provided for rapid re-housing programs (Dunton & Brown, 2019).

Most rapid re-housing programs target families or individuals meeting specific eligibility criteria, such as the Veterans Affairs Supportive Housing program that serves veterans. Although households served through these programs may include older adults, none are specifically targeted to older adults (Gubits et al., 2018). According to HUD guidelines, rapid re-housing is an effective intervention for different types of households experiencing homelessness, including those with no income, those with disabilities, and those with poor rental history (HUD Exchange, n.d.). Poor candidates for the intervention, per HUD guidelines, include those experiencing chronic homelessness and in need of permanent supportive housing, and those who are seeking a therapeutic residential environment, including those recovering from substance use disorders (HUD Exchange, n.d.). Additionally, individuals who are on fixed incomes and unlikely to increase their income over time (including older adults) may be poor candidates for the intervention as the housing assistance is time-limited.

### Permanent Supportive Housing

Permanent supportive housing is a non-time-limited intervention that combines rental assistance with voluntary supportive services for people experiencing chronic homelessness (National Alliance to End Homelessness [NAEH], 2021). Eligibility requirements for HUD-funded permanent supportive housing include one year or more of documented chronic homelessness,^6^ a documented disabling condition (e.g., chronic mental health conditions, chronic health conditions, and substance use disorders), limited income earning potential, and a need for intensive case management. Permanent supportive housing programs can be “site-based” (in an apartment building with multiple units) or “scattered-site” (with units spread throughout a community).

Permanent supportive housing is an effective solution to homelessness for older adults (Chung et al., 2018; Henwood et al., 2014; Lipton et al., 2000; Tsemberis et al., 2004), including those with mental health and substance use disorders (Kushel, 2020; Perl & Bagalman, 2015).

Investments in permanent supportive housing have helped decrease the number of chronically homeless individuals of all ages by 8 percent since 2007 (NAEH, 2021). In addition, through the use of permanent supportive housing the VA has seen reductions in chronically homeless veterans, the majority of whom are over the age of 51 (U.S. Interagency Council on Homelessness, 2018).

Permanent supportive housing is also cost-effective for people with complex health and social needs (Culhane et al., 2002; Metraux et al., 2003). For example, a study by Bamberger and Dobbins (2015) found that many formerly homeless older adults who were placed in nursing homes could be housed successfully in permanent supportive housing at lower cost and with more independence. Studies of permanent supportive housing serving all populations of adults document decreases in emergency room visits (Martinez & Burt, 2006), use of emergency detoxification services (Larimer et al., 2009), and incarcerations (Larimer et al., 2009), as well as increases in housing stability (Barrow et al., 2004).

Few studies examine outcomes of permanent supportive housing specifically for older adults. The few that are available compare older and younger adults experiencing homelessness. One study found that older adults in permanent supportive housing spent fewer days homeless, had less involvement with the justice system, and spent more time in independent/single-room occupancy and congregate/residential settings compared to younger adults in permanent supportive housing (Henwood et al., 2014). Evidence on other outcomes of permanent supportive housing for people experiencing homelessness, including severity of mental health conditions, quality-of-life, substance use, and hospital admissions, is mixed (Aubry et al., 2020).

“I think now the best thing that ever happened to me, for me to have my own house, to have a key. I can lay my head down and I don’t have to fear no one coming in, or being hurt, or anything like that.” – Male, 59

A number of permanent supportive housing programs across the country are tailored for older adults who have experienced homelessness.

Profile of Permanent Supportive Housing for Older Adults

In Los Angeles, the Southern California Clinical and Translational Science Institute is pilot testing the integration of the Community Aging in Place--Advancing Better Living for Elders (CAPABLE) program with permanent supportive housing for older adults who have experienced homelessness. CAPABLE is a short-term program that provides home-based services, such as visiting occupational therapists, nurses, and handypersons to older adults so that they can age in place. The Los Angeles pilot program provides CAPABLE services to formerly homeless older adults who are 50 years or older, live in permanent supportive housing, and experience difficulties with ADLs.

### Other Community-Based Housing Options for Older Adults

Housing for older adults is available through local housing providers and public housing agencies in the form of permanent subsidies (e.g., Section 8 Housing Choice Vouchers and Section 202 Supportive Housing for the Elderly vouchers), and low-income tax credit properties. Although these housing options are available to individuals who are at risk of or experiencing homelessness, eligibility for these options is open to a broader population of low-income older adults.

Subsidized Permanent Housing involves rental assistance programs that help low-income individuals afford housing in the private market. Low-income older adults may qualify for long-term housing assistance through public housing agencies that administer housing assistance programs and often develop and maintain affordable housing properties. The Housing Act of 1937 first established publicly supported housing to provide decent and safe rental housing for eligible low-income families, elderly persons, and persons with disabilities (HUD, n.d. a). Publicly supported housing includes a range of types, from scattered single-family houses and apartments to high-rise apartments for elderly households.

Two of the largest subsidized housing programs for older adults are the Supportive Housing for the Elderly (Section 202) and the Housing Choice Voucher (Section 8) programs. Section 202 provides rental assistance and supportive services to low-income households with net incomes of less than 50 percent of the area median income (or less than 30 percent in some properties) that include at least one member who is 62 years or older (HUD, n.d. b). Section 202 properties, operated by private and non-profit housing providers, are designed to accommodate individuals who need some assistance with ADLs by including grab bars and ramps in the apartments. Care and supportive services, such as meals, housecleaning, and transportation, are also typically available at these residences (HUD, n.d. b). The Section 202 program serves approximately 400,000 households annually (Couch, 2021); residents are, on average, 79 years old with an average income of less than $10,000. Ninety percent of residents are single women (Novak, 2018).

Housing Choice Vouchers, formerly referred to as Section 8, can be used in privately owned and managed properties (i.e., project-based vouchers) or in private units that residents select themselves (HUD, n.d.). These vouchers are available to households whose total annual income does not exceed 50 percent of the area median income.^7^ Eligibility for Housing Choice Vouchers is limited to U.S. citizens and non-citizens with eligible immigration status. Housing Choice Vouchers are not limited to seniors; however, as of 2016, half (51 percent) were elderly or disabled (Sard, 2018).

Low Income Tax Credit Properties provide another opportunity for affordable housing for older adults. The Low-Income Housing Tax Credit (LIHTC) program, created by the Tax Reform Act of 1986, provides tax credits for the acquisition, rehabilitation, or new construction of rental housing. LIHTC units are not limited to low-income households; however, 20 percent of units in LIHTC properties must be rented to households with incomes less than 50 percent of the area median income or 40 percent of units must be rented to households with incomes less than 60 percent of the area median income. According to HUD data on LIHTC tenant data, more than a third of households (33.8 percent) in LIHTC properties include at least one resident aged 62 or older (HUD User, 2019).

### Long-Term Care Options for Individuals with High Needs

Exhibit 5 outlines the types of residential long-term care available for individuals needing a high level of care. These options are primarily for individuals with debilitating health issues or serious conditions that require frequent medical supervision and round-the-clock care.

Exhibit 5 Types of Residential Long-Term Care Available for Older Adults Experiencing Homelessness

Type of Assistance | Description
Residential care | A range of congregate care settings that typically include housing, medical management, supportive services, and social activities
Institutional long-term care | Institutions such as nursing homes for individuals who can no longer live independently and need a significant amount of supervised care with meals, assistance with ADLs, and health management

Residential Care settings provide both housing and on-site supportive services for individuals who need some assistance with ADLs or some amount of supervision because of cognitive impairments. These residential care settings may provide housing, medical management, support services, social activities, and, in some cases, assistance with ADLs. Residential care settings are licensed at the state level. States and localities use over 30 terms to refer to group housing for older adults, and licensure requirements vary. Depending on the state terminology, size, and services offered these residential care settings can go by a number of names including Board and Care Homes, Adult Care Facilities, Residential Care Facilities, and Assisted Living Facilities (Lewin Group, 2011; n4a, n.d. a).

In some places, residential care homes provide room, board, and services but are not licensed by the state. Some operate legally, whereas others are operating illegally, raising concerns about the quality of such places. These homes often serve vulnerable individuals with limited financial resources.

In addition to residential care facilities, Adult Foster Care Homes provide room, board, and in-home supports offered in a home-like environment with shared living and dining areas. Most states limit the size of adult foster care homes to no more than five residents. The majority of costs associated with adult foster care are private pay, though some states offer limited support through their Medicaid State Plans.

The monthly costs of these residential care settings are far lower than nursing homes, but most of these residential care facilities are private pay. Financial assistance from Medicaid for supportive services within residential care settings can be covered through several different Medicaid authorities. The most common services are Medicaid Home and Community-Based Services (HCBS) 1915(c) Waivers and through the Medicaid State Plan Personal Care or Personal Assistance Services. In recent years, states have also started using Medicaid managed care to provide long-term services and supports.

However, Medicaid does not cover the housing portion of the cost of such residential care, and therefore cannot cover “room and board”. Some states have enacted policies to make such settings more available to lower-income residents. For example, some states limit the maximum amount that can be charged for housing or provide non-Medicaid assistance to Medicaid-eligible persons (e.g., a resident may spend their SSI income on the room and board and Medicaid covers the services or the state may provide a state-funded housing supplement). Finally, many states provide non-Medicaid state assistance to help older adults with low incomes afford assisted living. Veterans may qualify for assistance paying for congregate living through the VA’s Aid and Attendance or Housebound programs. In addition, Section 202 subsidies and other funding for housing can cover some of the housing costs for residents in certain facilities.

Institutional Long-Term Care is available for individuals who can no longer live independently and need a significant amount of assistance with ADLs. Nursing homes provide the most comprehensive package of services and are available to individuals who need 24-hour supervised care with meals, activities, and health management. A physician supervises each resident’s care, and a medical professional is almost always present. Like assisted living, costs vary depending on the level of care provided. Costs are extremely high, reaching an average of $8,000 per month. Medicaid will pay 100 percent of the cost of nursing home care for beneficiaries.

### Challenges with Housing Assistance for Older Adults Experiencing Homelessness

Perhaps the most significant challenge with housing assistance for older adults experiencing homelessness is that there is not enough housing available to meet the growing need among low-income older adults. The lack of affordable housing coupled with increases in the numbers of older adults eligible for housing assistance creates challenges in finding and maintaining housing for those experiencing homelessness. Only 37 affordable and available homes exist for every 100 extremely low-income renters in the United States (those with incomes less than 30 percent of the area median income), nearly a third of whom (30 percent) are seniors (Aurand et al., 2021). The number of low-income older adults who are eligible for rental assistance but do not receive it also has increased more than 5 percent between 2017 and 2018 (PAHRC, 2020). Although over time more older adults are living in publicly supported housing (increasing 2.9 percent between 2018 and 2019), the amount of affordable housing available is not keeping pace with demand. Adults living in the housing are aging, more older adults are entering public housing for the first time, and seniors living in publicly supported housing are staying longer, averaging 12.3 years in 2017, an increase of 5 percent since 2013. Yet the share of eligible seniors who receive housing assistance declined from 41 percent to 40 percent from 2017 to 2018 (PAHRC, 2020).

New funding for the Housing Choice Voucher program has been largely unchanged since 1983, and most appropriations maintain existing operations (Couch, 2020). With respect to Section 202 units, the supply is not sufficient to meet the growing number of adults who qualify, a challenge further exacerbated by low vacancy rates (Kochera, 2006) and having many facilities in need of repair (Libson, 2005). Long wait times for eligible older adults often result from these challenges. As an example, the length of time senior households spent on waitlist for public housing and Housing Choice Voucher increased by 18 percent between 2016 and 2017, from 22.9 months to 27 months (PAHRC, 2020).

“As far as getting housing and stuff, I really don’t have communication with the housing people. They just tell me I’m still pending or waiting for a place.” – Female, 60

As housing providers noted, lacking necessary vital documents such as a birth certificate or Social Security card, which can be lost through encampment sweeps or while staying on the street, can be a common barrier for older adults to receiving housing assistance. In addition, people experiencing homelessness are often unaware of their eligibility for housing assistance. The people with lived experience with whom we spoke were unaware of whether they qualified for housing assistance or reported long waitlists to get it. Others mentioned discrimination by landlords who did not want to rent to them because they experienced homelessness.

“A lot of [landlords] don’t want to house homeless people because of the baggage that comes with homeless people.” – Male, 62

### Expanded Services During the COVID-19 Pandemic

The CARES Act included a moratorium on tenant evictions from rental properties that receive federal funding or have Federal Government-backed mortgages from March 2020 until July 2020. The Centers for Disease Control and Prevention (CDC) announced an additional eviction moratorium on September 1, 2020, that was extended multiple times and ended in August 2021. In addition, some states, localities, territories, and Tribal areas, continue to implement statewide and/or local and county eviction moratoriums.

CARES Act funding also allowed communities to provide supportive housing services and more medium and long-term housing assistance, such as rental assistance and housing navigation services. Moreover, HUD granted waivers to all communities to help prevent the spread of COVID-19 and mitigate the pandemic’s economic impacts; these waivers included a suspension of time limits on temporary assistance programs, such as rapid re-housing, and a series that facilitate access to public housing. Waivers pertained to income verifications, review of citizenship and Social Security numbers, and proof of family composition for public housing tenants and inspections that were not possible or, in some instances, safe during the pandemic.

## HEALTH CARE, LONG-TERM CARE, AND BEHAVIORAL HEALTH SERVICES

Physical and behavioral health services play a critical role in the lives of many older adults experiencing homelessness due to the elevated incidence of health problems they experience relative to their housed counterparts (Cohen, 1999; Gelberg et al., 1990; HPRI, 2019; Brown et al., 2016). For many older adults at risk of homelessness, health expenses contribute to their becoming homeless (Bielenberg et al., 2020; Center for Housing Policy, 2015). The high cost of health care and long-term services and supports lead to extended periods of poverty for more than two-thirds of older adults aged 65 and older (Johnson & Favreault, 2021).

### Medicare and Medicaid

Health care, long-term care, and behavioral health services, including prescription medications, are available for older adults at risk of or experiencing homelessness through a variety of federal and state-funded mechanisms including Medicare, Medicaid, and VA benefits (for eligible veterans) among others. Benefits provided by each of these programs as well as the eligibility requirements vary within programs and across states. Medicare and Medicaid serve as the primary source of health insurance for older adults experiencing homelessness.

Medicare is a federally-funded health insurance program that helps with the cost of health care, but it does not cover all medical expenses or the cost of most long-term care. Beneficiaries can receive Medicare benefits through Medicare fee-for-service (FFS) (“traditional” Medicare) or Medicare Advantage plans. Medicare Advantage Plans are offered by private companies approved by Medicare. A key limitation of Medicare for older adults experiencing homelessness is its eligibility criteria. Medicare is limited to individuals aged 65 and older who have a work history or as an entitlement benefit to younger people receiving Social Security disability benefits for at least two years or with end stage renal disease.

Medicare-eligible individuals with low-incomes (i.e., in 2022, less than $1,153 per month for an individual and resources limited to $8,400, which would likely apply to a large majority of older adults experiencing homelessness) can receive additional coverage through the Qualified Medicare Beneficiary program (i.e., Medicare Savings Programs) (Medicare.gov, n.d.). The program provides financial assistance with part A premiums (hospital insurance), Part B (medical insurance) premiums, as well as with deductibles, coinsurance, and copayments for all individuals who meet the eligibility criteria.

Medicare typically provides full or partial coverage for services from doctors and other health care providers; outpatient care; preventive services such as screenings, vaccinations, and wellness visits; inpatient care in hospitals, skilled nursing facilities, and hospice care; and home health care, as well as for prescription drugs and some medical equipment such as wheelchairs and walkers. Medicare provides limited vision, hearing, and dental coverage for older adults.

In addition to physical health services, Medicare provides coverage for behavioral health services including depression screenings, diagnostic tests, individual and group psychotherapy, psychiatric evaluation, medication management, hospitalizations, and treatment of substance use disorders in both inpatient and outpatient settings.

Medicare is available to a wide range of older adults, but some Medicare Advantage special needs plans (SNPs), which are designed to provide targeted care and limit enrollment to defined groups of Medicare beneficiaries, are beginning to focus specifically on people experiencing homelessness. For instance, LA Care, a health plan based in Los Angeles, has partnered with SNP Alliance, Massachusetts General Hospital, and other academic, professional, and non-profit health care organizations to come up with a homelessness-focused Medicare Advantage SNP (Jain et al., 2020).

Medicaid provides health insurance for low-income Americans, including families with children, elderly people, and people with medically certified disabilities. Older adults ages 50-64 who are not yet eligible for Medicare but do meet income eligibility (133 percent of the federal poverty line) are also eligible for Medicaid in the 38 states and the District of Columbia that broadened their eligibility under the Affordable Care Act. However, in the 12 states that as of January 2021 have not expanded coverage under the Affordable Care Act, receipt of Medicaid by adults without children is rare (Garfield & Orgera, 2021). As of 2019, 10.5 percent of all adults ages 50-64 nationally were uninsured, for which the primary reason reported was that insurance was not affordable (Cha & Cohen, 2020).

Like Medicare, Medicaid typically provides full or partial coverage for a wide range of health services, including medical appointments, hospitalizations, preventive services, outpatient care, medications, and medical equipment as well as limited vision, hearing, and dental coverage. Medicaid coverage of behavioral health services, in contrast to Medicare coverage, varies greatly across states. All states provide some mandatory services for all Medicaid clients such as medically necessary inpatient hospital services, outpatient services, and institutional long-term care; however, Medicaid coverage for adults 65 and older varies by state for services such as detoxification, prescribed medications, targeted case management, rehabilitation services, therapies, medication management, clinic services, licensed clinical social work services, peer supports, and hospital stays.

State Medicaid programs can cover HCBS for individuals with disabilities and older adults with functional impairments (Costello, 2021) These services can include assistance with personal care, care coordination, and non-medical transportation. In addition, states can elect to cover housing-related services and supports, such as pre-tenancy services, home accessibility modifications, and transition services (Costello, 2021).

For individuals who are eligible for both programs, referred to as “duals”, Medicaid provides assistance for Medicare premiums as well as other services not typically covered by Medicare. As duals are a diverse population with extensive and complex needs, the Centers for Medicare & Medicaid Services (CMS) has developed the Financial Alignment Initiative in an effort to work with states to improve the coordination of all Medicare and Medicaid covered benefits and enhance the care provided to dually eligible beneficiaries. As of January 2020, 11 states are participating in this initiative (CMS, 2022).

Increasingly, to meet the needs of individuals with complex medical needs such as older adults experiencing homelessness, providers and funders are offering coordinated care models that integrate primary care, behavioral health services, and social services through a single program. For example, PACE is a Medicare program, available as a state Medicaid option, that provides comprehensive medical and social services to certain frail, community-dwelling elderly individuals, most of whom are dually eligible for Medicare and Medicaid (Medicaid.gov, n.d.). In several communities, this model is being implemented in partnership with housing providers and targeted specifically to older adults experiencing homelessness.

Profile of Coordinated Care Models for Older Adults

St. Paul’s PACE program in San Diego, California, provides a coordinated model of care to formerly homeless older adults aged 55 years or older who are dually eligible for Medicare and Medicaid. In partnership with local housing developers, older adults are provided subsidized housing with wrap-around supportive services, including primary and specialty health services, medication assistance, mental health services, occupational therapy, dentistry, as well as meals and nutrition counseling, social activities, social services, and transportation assistance. This program reports reduced hospital use among older adults and lower rates of hospital readmissions and potentially avoidable hospitalizations, such as for congestive heart failure and asthma (Meret-Hanke, 2011; Segelman et al., 2014).

### Veterans Affairs Health Care

Some older adults at risk of or experiencing homelessness may also be eligible for health care through the Veterans Health Administration (VHA). Eligibility includes having served prior to September 7, 1980; having served after September 7, 1980, and served for 24 months or the full period of active duty; having been discharged for a disability that was caused or made worse by active-duty service; and having been discharged for a hardship.^8^ Of the 8.7 million veterans enrolled in health care through the VHA in 2021, 30 percent (2.6 million) were between ages 45 and 64, and 49 percent (4.2 million) were over age 65 (Wang et al., 2021; Vespa, 2020). According to HUD, 55 percent of the veterans experiencing sheltered homelessness in 2021 were aged 55 or older (HUD, 2023).

VHA benefits typically offer coverage for services and medications comparable to Medicare and Medicaid; however, VHA health care benefits are not the same for all participants and are subject to change based on funding availability. Participants are assigned to different priority levels according to various factors, such as income and whether they have any medical condition that derives from their military service. If federal funding for VHA health care drops or does not keep pace with costs, individuals in the lower priority groups may lose VHA coverage.

VHA benefits also provide coverage for behavioral health treatment, including a broad range of mental health conditions, substance use disorders, post-traumatic stress disorder, and serious mental illness through both inpatient and outpatient settings. Moreover, general and psychogeriatric mental health services are provided as an integral part of primary care within the Patient Aligned Care Teams as well as VHA nursing homes and residential care facilities where many veterans receive care. The VHA also has a set of programs that fall under the heading Geriatrics and Extended Care, which are designed to help veterans diagnosed with chronic health issues or life-limiting illnesses. Among other things, these programs can provide respite care, adult day care, outpatient and inpatient hospital services, nursing homes, palliative care, and hospice.

### Older Americans Act Funded Programs

Older adults experiencing homelessness may also benefit from health and support programs available through Older Americans Act (OAA) funded programs. The OAA coordinates the distribution of funds for many programs for older adults, both health-related and otherwise (ACL, 2022). These funds originate with the federal Administration of Aging, which oversees 56 State Units on Aging, which in turn oversee over 600 Area Agencies on Aging and almost 300 Tribal organizations, totaling around 20,000 service providers (ACL, n.d.; Siegler et al., 2015). The OAA funds a number of programs and services directly, such as Aging and Disability Resource Centers, Elder Rights Support programs, and the Alzheimer’s Disease Initiative (Congressional Research Service, 2022). However, the majority of OAA funds (72.8 percent in FY2022) go directly to State Units on Aging and Area Agencies on Aging, which allocate funds locally to address the health and social needs of their constituents (Congressional Research Service, 2022). One such source is the Title III-D Disease Prevention and Health Promotion grant, which Area Agencies on Aging use to fund evidence-based disease prevention and health promotion services in settings such as senior centers, community centers, and various congregate settings (California Department of Aging, n.d.).

One important development in recent years is the No Wrong Door System initiative, a collaborative effort by the Administration for Community Living (ACL), CMS, and VHA. The initiative strives to create a more consumer-driven, efficient system for accessing long-term services and supports for older adults and individuals with disabilities services. Since 2003, the No Wrong Door initiative has supported 33 states with funding to help transform their systems to make it easier for consumers and their families to learn about the services available and how to access them (ACL, 2022).

### Substance Abuse and Mental Health Service Administration Funded Programs

Older adults experiencing homelessness with mental health and/or substance use disorders can access services through programs of the Substance Abuse and Mental Health Services Administration (SAMHSA), a federal agency within HHS (SAMHSA, n.d.). Individuals can receive comprehensive care, including 24/7 crisis services, referrals to clinics and services, and care coordination, through Certified Community Behavioral Health Clinics (CCBHCs), or through SAMHSA’s National Helpline (SAMHSA, n.d.). CCBHC services are available to individuals of all ages and are free for those unable to pay (SAMHSA, n.d.). SAMHSA also provides a variety of grants to states and local organizations specifically assisting those experiencing co-occurring homelessness and behavioral health disorders with a variety of services, including case management, peer support, and treatment for mental health and substance use disorders (SAMHSA, n.d.).

### Other Sources of Health Care

Older adults, including those who may be uninsured, can also access health care through community-based outpatient clinics including Federally Qualified Health Centers (FQHCs), Health Care for the Homeless clinics, Community Health Centers, Migrant Health Centers, and Primary Care in Public Housing (Health Resources and Services Administration [HRSA], 2018). Each of these organizations is grant-funded to provide specific services to underserved populations.

In particular, the Health Care for the Homeless Program supports FQHCs that provide health care to people experiencing homelessness. Anyone experiencing homelessness is eligible to receive assistance from a Health Care for the Homeless clinic, though clinics are primarily located in urban locations. Eligibility includes people living in unsheltered locations, shelters or transitional housing, “doubled-up” situations with family or friends, people exiting institutions without a stable housing situation, and people in any other unstable or non-permanent living situation. Nearly 300 Health Care for the Homeless clinics across the country provide primary health, mental health, substance use disorders, and social services with intensive outreach and case management to link clients with additional services. In 2020, Health Care for the Homeless clinics served nearly 1 million patients, with 7.43 percent over the age of 65, a proportion that has been steadily increasing in recent years (HRSA, 2020).

### Challenges with Health Services for Older Adults Experiencing Homelessness

Older adults experiencing homelessness face a number of challenges accessing the health care they need, including lack of health insurance; a need for immediate focus on basic needs, such as food and housing, instead of health needs; limited appointments and providers; a lack of transportation to access assistance (Canham et al., 2020; Kushel et al., 2012; Watson et al., 2008) among others.

Lack of insurance: There are no nationally representative data on rates of health insurance coverage for older adults experiencing homelessness; however, two studies have been conducted in single cities. These studies found that the majority of older adults experiencing homelessness have some type of health insurance, with Medicare and Medicaid being the primary sources (Lee et al., 2020; Ye et al., 2019). Using Homeless Management Information Systems data on 1,204 older adults aged 55-90 living in Tampa, Florida who received homelessness assistance in the last year, Lee and colleagues (2020) found that 88 percent had insurance. Similarly, in a study of 17 older adults experiencing homelessness in Wilmington, Delaware, Ye and colleagues (2019) found that all but two participants reported having health insurance.

Older homeless adults who lack health coverage tend to be aged 50-65 and fall between the cracks of governmental safety nets -- not old enough to qualify for Medicare and ineligible for Medicaid assistance in many states (Dipietro et al., 2014). In an examination of the Health Care for the Homeless User Survey, Baggett and colleagues (2011) found that, among people experiencing homelessness, those aged 45 and older were more likely than younger adults to have an unmet need for prescription medications (2010).

Primary focus on basic needs: Many older adults experiencing homelessness, including those with health insurance, do not receive the health care they need because they first focus on addressing their basic and immediate needs, such as securing shelter and food (Baggett et al., 2011; Van Dongen et al., 2019). This delay of attention to medical needs often results in older adults experiencing homelessness relying on emergency departments and street outreach programs for health care (Chung et al., 2018; McDonald et al., 2006).

Limited appointments or providers: Some research has found that over half of adults aged 50 and older who are experiencing homelessness report having access to a regular place of care (Chung et al., 2018; Kaplan et al., 2019). Access to health care, including routine exams or wellness checks, for older adults who are experiencing homelessness is still lower than their housed counterparts, due in part to individuals not knowing where to go or inability to get and keep appointments (McDonald et al., 2006; Ye, 2019). Moreover, older adults with memory problems may struggle to attend scheduled appointments (Grenier et al., 2013).

Lack of transportation: In the limited research available documenting older homeless adults’ barriers to receiving needed health care, research found that a lack of transportation to appointments or difficulty navigating public transportation was cited as among the most common reasons for lack of health care receipt among older adults experiencing homelessness (Canham et al., 2020; Ye et al., 2019).

In discussions, people with lived experience noted barriers to service receipt including unreliable telephones, inability to get walk-in appointments, appointments that were too far out to remember, and, for two individuals, lost Medicaid cards which prevented them from getting the health services that they needed.

“I have trouble keeping [appointments] because I forget a lot.” – Female, 60

Additionally, in discussions, experts and housing providers noted that behavioral health care services are rarely tailored to geriatric populations. Conditions related to aging, such as memory problems, may be interpreted as behavioral health problems. Moreover, if behavioral health providers are not attentive to feelings common to older adults, such as shame and distrust of assistance, they will be less effective in providing them the assistance they need.

### Expanded Services During the COVID-19 Pandemic

Various new policies and practices were put into place to facilitate access to health care during the COVID-19 pandemic. HRSA’s COVID-19 Coverage Assistance Fund and COVID-19 Uninsured Program covered the costs of administering COVID-19 vaccines to uninsured and underinsured patients. CMS expanded Medicare coverage of telehealth and provided payment policy and regulatory flexibility for Medicare-covered services. In addition, the Families First Coronavirus Response Act required that Medicaid programs keep people continuously enrolled through the end of the month in which the COVID-19 public health emergency ends.

## INCOME SUPPORTS AND OTHER NEEDS

### Income Supports

SSI, SSDI, and state-funded general assistance programs provide income supplements to aged, blind, and disabled people (and some family members) to help meet basic needs such as food, clothing, and housing. As of 2022, an eligible individual’s monthly maximum federal SSI payment was $841. All but four states supplement this amount with additional assistance ranging from $10 to $400 a month. SSDI payment amounts are based on an individual’s lifetime average earnings before becoming disabled, with average monthly amounts ranging from $800 and $1,800. Because many older adults live on fixed incomes, another strategy some communities are exploring to assist older adults is to provide shallow rental subsidies (typically several hundred dollars a month of limited, needs-based payments), such as Santa Monica’s Preserving Our Diversity program, which provides rental assistance to low-income seniors to maintain their housing (Sharma, 2019).

For people who were employed and lost their jobs, unemployment insurance benefits can provide some temporary income supports. The basic unemployment insurance program is operated by individual states and overseen by the DoL. Most states provide up to 26 weeks of benefits, replacing about half of a recipient’s wages, on average (Stone & Chen, 2014). Eligibility and benefit levels differ by state. Some recipients may also be eligible for the Extended Benefit program, which provides an additional 13-20 weeks of compensation to workers if the state’s unemployment situation has worsened. Studies estimate unemployment rates among people experiencing homelessness range from 57 percent to over 90 percent compared to less than 5 percent for the general population (HPRI, 2020); however, it is not clear how many older adults experiencing homelessness are eligible for or receive unemployment insurance benefits.

Providers and organizations can assist older adults experiencing homelessness with the application process to apply for these benefits (Perret, 2021; Brown et al., 2013). The SOAR program, an evidence-based model, also helps older adults with mental illnesses, co-occurring substance use disorders, or other impairments to apply for SSI and SSDI (Kushel, 2020). One study found that SOAR applicants were twice as likely to have their initial application approved than all other homeless applicants (Kauff et al., 2016). On a national level, SOAR applicants who were of older age and living in an institutional setting, such as a hospital or a residential treatment center, were associated with a higher rate of application approval among homeless adults at risk of or experiencing homelessness (Lowder et al., 2017).

### Food and Nutrition Assistance

Administered by the USDA, SNAP provides monthly benefits to low-income households to purchase food. It is the largest USDA food assistance program, serving more than 5 million older adults annually (U.S. Government Accountability Office, 2019). SNAP is funded through “mandatory” federal funding, meaning that funding for the program is automatically expanded or contracted to meet demand (Blancato & Whitmere, 2021). State Units on Aging and Area Agencies on Aging also provide nutrition services to adults aged 60 and older. For example, Meals on Wheels is a program that delivers meals to home-bound individuals who are unable to purchase or prepare their own meals.

### Transportation Assistance

Transportation assistance for older adults experiencing homelessness is available through a range of services. At the state level, the Aging Services Division provides a range of services to eligible older adults, including transportation to shopping and medical appointments (Eldercare Directory, n.d.). Eligible older adults may contact their local offices to arrange for transportation to medical appointments and shopping centers, among other locations. Older adults who need special accommodations, such as those who use a wheelchair or have other mobility impairments, can use the accessible transportation.

Although service availability and eligibility differ from state to state, older adults receiving Medicaid coverage may use travel services to reach medical facilities. The transportation voucher program involves assistance with fares or rides without charge to eligible low-income older adults and people with disabilities (Haarstad, 2008). In addition, Medicaid Advantage plans have flexibility to offer expanded benefits that go beyond Medicare FFS and can address barriers to health, including non-emergency transportation to and from doctor’s appointments, lab tests, pharmacies, massage therapy, fitness centers, and other health care-related destinations.

### Social Engagement Services

Many communities offer services to combat social isolation that many older adults experience, including senior centers, adult day centers, and in-home social engagement programs, though few of these programs are specifically for older adults experiencing homelessness. These programs are often funded through Area Agencies on Aging but can be supported through other federal, state, and municipal sources as well as through faith-based and private sources. Such services typically provide wellness and exercise classes, arts programs, and community building opportunities (ACL, n.d.; Berg-Weger et al., 2020; Siegler et al., 2015). The availability of such programs, the services they provide, and eligibility for participation vary nationally.

### Adult Protective Services

Adult protective services (APS) programs respond to allegations of abuse, neglect, or exploitation of vulnerable adults, such as older adults and those with disabilities (National Adult Protective Services Resource Center [NAPSRC], n.d.). They investigate allegations and, as needed, address the health and safety needs of the victims through providing a range of services and case management (NAPSRC, n.d.). APS programs collaborate with a number of professionals in the health, safety, and social services fields to address allegations as well as other needs victims may require (National Adult Protective Services Association, n.d.). States receive the majority of their funding for APS programs from the Federal Government through the Social Services Block Grant, which they can supplement through general revenue funds or other funding intended for older adults, such as funding through the OAA (Ramsey-Klawsnik, 2018). Program administration varies by state and can occur at the state level, the county level, through local agencies such as Area Agencies on Aging, or some combination of all three (Ramsey-Klawsnik, 2018). Each APS program can determine its own eligibility and reporting requirements in addition to definitions of abuse, neglect, and exploitation; some programs offer services only to adults over age 60, while others use varying combinations of age and disability to determine eligibility (Ramsey-Klawsnik, 2018).

### Challenges with Income Supports and Other Needs

Older adults experiencing homelessness face a range of challenges in accessing assistance and services for meeting basic needs, such as income, food, and transportation. People experiencing homelessness may have difficulty accessing financial benefits for which they are eligible. Individuals with serious mental illnesses, medical impairments, or substance use disorders and who are at risk of or experiencing homelessness face challenges when applying for SSDI benefits (Donaldson et al., 2020). Some applicants find it difficult to produce the documents needed to establish or maintain their eligibility.

Studies have also identified several barriers in accessing food assistance programs among older adults experiencing homelessness, such as difficulty applying for or renewing their benefits due to limited access to technology and no fixed addresses, low health literacy, and cognitive impairment, that may complicate the ability to understand eligibility criteria and complete necessary documentation (Tong et al., 2018). USDA researchers suggest that older adults, especially those who have been self-sufficient for the majority of their life, may feel stigma around receiving welfare, especially in a public setting such as a grocery store (SNAP, n.d.). Data on the rate of SNAP participation for older adults experiencing homelessness are not available, yet data for all eligible elderly households indicate that only about a third participates in SNAP (e.g., Ziliak & Gundersen, 2020). In response to the low participation levels and unique economic circumstances of elderly households, the USDA Food and Nutrition Service has implemented waivers and demonstration projects that aim to reduce barriers to participation, reduce administrative burden, and improve access to SNAP for elderly people (Levin et al., 2020).

In discussions, experts and providers echoed this sentiment, noting that many older adults experiencing homelessness or recently placed in housing need assistance applying for and maintaining benefits, including SSDI, SNAP, and others, especially those older adults who are not internet savvy, do not have access to the necessary technology, or struggle to understand the steps required to apply for and maintain their benefits. Among people with lived experience of homelessness, two reported needing help navigating the recertifications for their benefits and, in particular, being confused by all of the mail they received from different agencies. Others reported not knowing how computers worked and feeling frustrated that they needed to use computers to apply for benefits and other assistance.

“For me, I don’t know how the computer works… Everything now you have to do it on the computer.” – Male, 66

Yet an additional challenge for older adults experiencing homelessness is that SNAP does not allow recipients to purchase prepared food, thus requiring access to cooking facilities and an ability to safely store uncooked food (Tong et al., 2018). However, several states (five as of April 2022) have implemented a SNAP Restaurant Meals Program that allows select SNAP recipients to use their SNAP benefits to pay for restaurant meals. Eligibility differs across states but is typically limited to SNAP recipients who are 60 years or older, are experiencing homelessness, or have a disability (USDA, 2021).

Transportation assistance is available for many older adults experiencing homelessness; however, barriers can limit access to some services, particularly for those in rural areas and with mobility limitations (Ravensbergen et al., 2022). Limited research is available on the accessibility of public transportation for older adults, though the literature suggests significant variation by city (Ravensbergen et al., 2022). Individuals with lived experience with homelessness reported transportation difficulties, including not knowing how to navigate bus systems and feeling vulnerable with using public transportation due to poor eyesight and the lack of proper eyewear, physical limitations, or memory problems.

“[My case manager is] going to give me bus passes, but the problem is that my eyesight and it’s just not good and I just don’t feel, I feel vulnerable out there.” – Female, 59

### Expanded Services During the COVID-19 Pandemic

Assistance to meet a range of older adults’ basic needs were expanded during the COVID-19 pandemic. The pandemic exacerbated food insecurity for older adults at risk of or experiencing homelessness due to a loss of, or disruption in, food from nutrition programs (Goger, 2020). To address this challenge, numerous providers implemented innovative strategies, such as converting in-person nutrition programs for older adults into “grab and go” programs or home-delivered meals. Additionally, when some traditional senior nutrition food distribution channels were overwhelmed, providers found new local and corporate partners. For example, members of National Association of Nutrition and Aging Services Programs (NANASP) and n4a partnered with Tivity Health to provide Nutrisystem and South Beach Diet frozen home-delivered meals to older adults in areas with food shortages. A January 2021 survey of the NANASP members found that around 90 percent of respondents reported that they were still serving more meals now than prior to the pandemic, with many providers stating that their demand had doubled or more (NANASP, 2021).

During the pandemic, states began more widespread adoption of the USDA’s SNAP Online Purchasing Pilot to allow SNAP participants the option of grocery shopping online, which prior to March 2020 was in place in only New York and Washington State. The program has continued to expand following the pandemic. As of April 2023, the District of Columbia and every state except Alaska were participating in the program (USDA, 2021).

In addition, during the pandemic, federally-funded unemployment insurance was expanded to include workers not traditionally covered by unemployment insurance benefits, provide a flat benefit level to all recipients (at a higher rate than was typically provided by states), and extend the period of time for which recipients could receive benefits.

In 2021, the Federal Government drastically increased its direct contribution to APS programs through the CARES ACT and the American Rescue Plan Act (ACL, 2021). No formal APS administration changes happened at the federal level in response to the pandemic, though some APS programs took on larger roles in service referrals and direct provision as community-based organizations and nursing homes struggled to stay open and provide care for older adults (Liu & Delagrammatikas, 2021).

Providers with whom we spoke noted that several changes implemented during the pandemic had both positive and negative impacts for the older adults they served. For example, multiple housing providers were able to provide iPads or other devices to their residents, expanding the ways to connect with family and friends; however, older adults with limited technological proficiency were less able to use these new methods of connection. For these older adults, the pandemic was thought to accelerate physical and cognitive decline. Similarly, many meal services such as soup kitchens transitioned to meal delivery assistance. This shift was an advantage for those who struggled to access services, yet also removed an opportunity for socialization for many older adults.

3 Two separate ERA programs were established: ERA1 provides up to $25 billion under the Consolidated Appropriations Act, 2021, which was enacted on December 27, 2020, and ERA2 provides up to $21.55 billion under the American Rescue Plan Act of 2021, which was enacted on March 11, 2021. ERA1 ended in September 2022. ERA2 is set to expire in September 2025.

4 The terms crisis and interim housing are typically used interchangeably to denote temporary housing situations people experiencing homelessness may live while looking for permanent housing. In contrast to emergency shelter and motel vouchers, transitional housing often includes more supportive services and allows longer stays, often up to 24 months.

5 Housing First indicates individuals move into permanent housing directly from homelessness rather than spending a period of time in temporary, service-rich interventions, such as transitional housing, before entering housing.

6 Chronic homelessness includes one year of consecutive homelessness or four or more episodes of homelessness within the last three years that accumulate to at least one year.

7 A public housing agency is required to provide 75 percent of its vouchers to applicants whose incomes do not exceed 30 percent of the area median income.

8 A hardship discharge is a mechanism through which activity members of the military can be released from duty due to hardship such as the death or permanent disability to the member’s immediate family, such as the spouse who is the primary guardian to the children of the family when the military personnel would be deployed.