# Section 2 Size, Characteristics, and Needs of the Population of Older Adults Experiencing Homelessness

## PREVALENCE OF HOMELESSNESS AMONG OLDER ADULTS

Homelessness among older adults is increasing, with a growing proportion of the population experiencing homelessness aged 50 and older. ^1^

People aged 50 and older are the fastest-growing age group of those experiencing homelessness, and their numbers are estimated to triple by 2030 (Culhane et al., 2019). According to the U.S. Department of Housing and Urban Development (HUD), in 2021, people aged 55 and older composed 19.8 percent of the sheltered homeless population (HUD, 2023), an increase from 17.9 percent in 2020. This rate is even higher when we focus on adult-only households experiencing homelessness: 28.7 percent in 2021 (HUD, 2023). Among sheltered homeless adults with chronic patterns of homeless, those aged 55-64 made up the largest share of people experiencing chronic homelessness (27.0 percent), and a total of 35.7 percent were aged 55 and older in 2021 (HUD, 2023). The percentage of individuals aged 51 and older in emergency shelters, transitional housing, and safe havens increased more than 10 percent in a decade, from 23.0 percent in 2007 to 33.8 percent in 2017^2^ (HUD, 2018). Among people experiencing sheltered homelessness, people ages 55-64 compose a larger proportion (14.7 percent in 2021) than those ages 65 and older (5.1 percent in 2021) (HUD, 2023). In addition, the percentage of older adults in permanent supportive housing grew during this time from 23.9 percent in 2007 to 38.7 percent in 2017 (HUD, 2018).

Age is the predominant way to define older adults experiencing homelessness, though the specific age is not universally agreed upon in the literature or in practice.

Most current research on older adults at risk of or experiencing homelessness focuses on those who are 50 and older. The experts with whom we spoke agreed that defining older adults in this way makes sense for both research and practical purposes, because the health and mobility of adults experiencing homelessness at age 50 is similar to that of housed adults who are 15-20 years older. Housing and service providers, on the other hand, noted that they are often required to define older adults as age 55 and older or 62 and older because of eligibility restrictions imposed by their programmatic funding sources. For example, Supportive Housing for the Elderly vouchers provide rental assistance and supportive services to low-income households that include at least one member who is 62 years or older. Individuals 55 and over are eligible for other HUD-funded assistance for elderly and disabled households such as Housing Choice Vouchers and public housing. Nutrition assistance, such as Meals on Wheels, is provided by State Units on Aging and Area Agencies on Aging to adults aged 60 and older. To provide services to individuals under 55, service providers often must use private funding sources.

A couple of experts suggested, however, that defining “older adults” among those experiencing homelessness, especially in relation to determining eligibility for assistance, should be based on individuals’ health needs or functional limitations rather than age-based criteria alone. They noted that many adults experiencing homelessness in their 40s and 50s have disabilities requiring the same level of services and supports typically provided to older adults. Moreover, due to increased mortality rates among people experiencing homelessness, many of these individuals never reach “older adult” ages. One provider indicated, however, that there was insufficient age granularity in data collected on adults experiencing homelessness to best determine at which ages physical and mental health vulnerabilities are heightened, knowledge that could help guide the categorization of older adults among those experiencing homelessness.

## PATHWAYS INTO HOMELESSNESS FOR OLDER ADULTS

Income supports for older adults at risk of homelessness are often insufficient to cover their expenses.

SSI and SSDI are often the primary sources of income for older adults at risk of or experiencing homelessness, with earned income, panhandling, and monetary assistance from relatives as supplementary sources (Cohen et al., 1999; Garibaldi et al., 2005; Gonyea et al., 2010). These income supports are often insufficient to cover the cost of housing and other expenses (Airgood-Obrycki, 2019). Living on limited, fixed incomes, older adults experience housing cost burden more frequently than the general population, potentially resulting in housing loss (Sermons & Henry, 2010). According to the Joint Center on Housing Studies of Harvard University, people older than age 50 have the highest risk of paying more than 30 percent of their income on rent or mortgage, with as many as one half of renters ages 50 and older doing so in 2018 (Joint Center for Housing Studies, 2018). Approximately 10 million households headed by someone over age 65 pay at least 30 percent of their income on housing, and half of those pay over 50 percent (Joint Center for Housing Studies, 2019). Nationally, more than 1.7 million extremely low-income renter households with an older adult are severely cost-burdened, spending more than half their income on rent (Prunhuber & Kwok, 2021). Being cost-burdened by housing limits resources available for other expenses, including health care, transportation, and healthy food. With an overwhelming portion of their incomes dedicated to rent, many severely rent-burdened older adults go without heat, food, or medication to pay their rent (Prunhuber & Kwok, 2021). Cost-burdened older adults are more likely to report an inability to fill a prescription or adhere to health care treatments due to cost (Center for Housing Policy, 2015). Moreover, the challenge of affording housing on limited incomes is exacerbated for Black and Latinx older renters, who are more likely than White older renters to have insufficient income and few assets as they enter retirement years (Prunhuber & Kwok, 2021).

The population of older homeless adults is comprised of two subgroups with different trajectories into homelessness.

The growth of homelessness among older adults can be attributed to two trends: aging of those who first experienced homelessness earlier in life and continue to experience homelessness as older adults, and those experiencing homelessness for the first time in older age.

Older adults who first experienced homelessness earlier in their lives represent a cohort effect: individuals born in the second half of the post-World War II baby boom (1954-1963) who have had an elevated risk of homelessness throughout their lives and have reached aged 50 and older in the last decade (Culhane et al., 2013). This group of individuals became adults in a time when there was an oversupply of workers and undersupply of housing, resulting in depressed wages, high unemployment, and increased rents. These inauspicious circumstances combined with back-to-back recessions in the late 1970s and early 1980s contributed to intermittent employment in low-wage jobs and frequent periods of unemployment (Culhane et al., 2013), and subsequently, increased vulnerability to housing instability and homelessness throughout their lives. Moreover, this group of older adults experiencing homelessness typically have had more risk factors (e.g., mental health and substance use disorders) for homelessness throughout their lives than older adults who first experience homelessness after age 50, thus increasing their vulnerability to homelessness throughout their lives (Culhane et al., 2013; Brown et al., 2016). In discussions, experts and providers noted that whereas these individuals may have initially entered homelessness as younger adults due to economic factors, they often are unable to regain long-term stability due to physical or behavioral health challenges.

The second group of older adults are people who experience homelessness for the first time after age 50, largely due to economic instability in their later years. In the Health Outcomes in People Experiencing Homelessness in Older Middle Age (HOPE HOME) study, almost one-half of the 350 older adults included in the sample (43 percent) had not experienced homelessness before age 50 (Brown et al., 2016). In a qualitative study including 79 older adults experiencing homelessness, Shinn and colleagues (2007) similarly found that over half of the respondents lived relatively stable lives, typically involving long periods of employment and residential stability, before becoming homeless at an average age of 59. In an international study of adults aged 50 and older newly experiencing homelessness in Boston, England, and Melbourne, Crane and colleagues found that only about one-third of the sample had experienced homelessness prior to the current episode (Crane et al., 2005). For older adults experiencing homelessness for the first time, homelessness is often caused by stressful life events, such as the death of a spouse, divorce, loss of work, eviction, or the onset of health problems, coupled with limited or fixed incomes (Cohen, 2004; Crane et al., 2005). Seniors and people with disabilities compose nearly half of renters with extremely low incomes (i.e., at or below the poverty guideline or 30 percent of the area median income) (Aurand et al., 2021), making them vulnerable to homelessness when stressful events occur (Brown et al., 2016; Kushel, 2020).

Experts and providers reinforced these findings: older adults relying on decreased or fixed incomes often cannot withstand rising housing costs, including increasing rents, increasing property taxes, and ongoing home maintenance costs. One expert noted that most states do not have rent control or eviction protection. Another noted that few, if any, tax relief programs are available nationally for older adults who cannot afford their property taxes, so increasing house values can lead to financial strain even for those who own their own homes. Additional factors experts and providers noted that can exacerbate older adults’ risk of homelessness include financial exploitation, decreased perception of risk that can accompany cognitive aging, and loss of social supports as family and friends move or pass away. Multiple interviewees reported that individuals who have been self-reliant for many years often do not reach out for assistance until their situation is dire due to shame or lack of knowledge about the supports available offered and how to navigate the system.

These findings also were reflected in the experiences of the people with lived experience with whom we spoke. Among the 14 older adults we engaged in conversation, the majority indicated they had multiple experiences with homelessness throughout their lifetimes; two people experienced homelessness for the first time as older adults. Both of the newly homeless individuals reported their homelessness was caused by changes in their incomes. One individual lost her housing when her rent increased and her husband’s income declined. Another lost his housing when health problems prevented him from doing his job. Among those who had previous experiences with homelessness, four people attributed their recent experiences to mental health issues and substance use disorder, and two people reported physical injuries led them to lose their jobs and subsequently their housing. Two people reported having lost their most recent housing when a loved one passed away and one person reported his house burned down and they had no other place to go. The remaining three individuals did not cite a cause for their recent homelessness.

“I got peripheral neuropathy in my hands. My occupation was a ballet accompanist. When my hands started getting numb from the peripheral neuropathy, I could not do that, the line of work, anymore… That was the first time that I was not working.” – Male, 65

## CHARACTERISTICS OF OLDER ADULTS EXPERIENCING HOMELESSNESS

Older adults who experienced homelessness earlier in life differ significantly on a range of characteristics and needs from older adults who first experience homelessness after the age of 50.

Early evidence suggests that older adults who experienced homelessness earlier in life have had more vulnerabilities throughout their lives than older adults with later entry into homelessness. Older adults with earlier experiences of homelessness have more adverse childhood experiences, chronic medical conditions, drug use, and out-of-home placement during childhood; more mental health, alcohol and drug use, and incarceration during young adulthood; and more underemployment, drug use, and traumatic brain injury during middle adulthood (Brown et al., 2016). In contrast, individuals with later onset homelessness have typically been married, held jobs, and maintained housing in the past but experience homelessness for the first time after age 50 (Brown et al., 2016; Shinn et al., 2007). Although often living in poverty throughout their adult lives, these individuals have long work histories, usually in low-paying, physically demanding work.

Exhibit 1 Sample Racial/Ethnic Composition for Studies of Older Adults Experiencing Homelessness

Category | Studies of Older Adults Experiencing Homelessness
Study | Brown et al., 2010 | Brown et al., 2015 | Garibaldi et al., 2005 | | Gordon et al., 2012
Location | Oakland | Boston | Pittsburgh and Philadelphia | | Multi-site
Sample ^1^ | 776 older adult attendees (50 and older) at an outreach event | 204 older adults (50 and older) recruited from emergency shelters | 74 older adults (50 and older) recruited from unsheltered enclaves, shelters, and transitional housing or singleroom occupancy dwellings | | 408 older adults (55 and older) experiencing homelessness with mental illness
Racial/Ethnic Composition of Sample ^2^
Black/African American | 54% | 40% | 81% | | 28%
White/Caucasian | 29% | 40% | 19% | | 60%
Latino | 8% | 10% | -- | | --
Multiracial/Other races | 9% | 9% | -- | | 13%
Racial/Ethnic Composition of Overall Population ^3^ | Oakland | Boston | Pittsburgh | Philadelphia | N/A
Black/African American | 22% | 24% | 23% | 41%
White/Caucasian | 29% | 44% | 64% | 35%
Latino | 27% | 20% | 4% | 15%
Multiracial/Other races | 9% | 10% | 5% | 5%

1 These samples of older adults are often sub-sets of larger samples included in the studies.

2 Terminology reflects that used in the included studies.

3 U.S. Census, 2021.

Those who first experienced homelessness prior to age 50 typically have experienced homelessness for longer periods of time overall and in their current or recent episodes.

Not surprisingly, older adults who first experienced homelessness prior to age 50 have spent more time homeless (4.2 years) than those individuals whose first homelessness occurred at age 50 or older (2.0 years) (Brown et al., 2016). In the HOPE HOME study, the two groups also differed in the length of their current episode of homelessness. Nearly three-fourths (73 percent) of those with first homelessness before age 50 were continuously homeless for one year or longer in their current episode, compared to 60 percent of those who first experienced homelessness after the age of 50 (Brown et al., 2016). Those with earlier experiences of homelessness also spent a greater period of time during the three-year follow-up period living in unsheltered and institutional settings (shelters, jails, transitional housing), whereas individuals newly experiencing homelessness as older adults spent greater periods of time cohabiting or living in rental housing during the follow-up period (Lee et al., 2016).

The limited data available on the racial/ethnic composition of the population of older adults experiencing homelessness suggests an overrepresentation of people of color.

Data on racial/ethnic composition for this population are available only from a handful of regional studies. Exhibit 1 provides the racial/ethnic background of each of the study populations. These studies vary considerably in the geographic area in which they are set and in the sampling strategies used to identify the population. Despite the differences in how they were conducted and in their specific findings, each study found a larger percentage of African Americans experiencing homelessness than the broader population, a finding that is similar to national data on the overall population of people experiencing homelessness (HUD, 2020; Moses, 2019).

## SERVICE NEEDS OF OLDER ADULTS EXPERIENCING HOMELESSNESS

In this section, we review the service needs of older adults experiencing homelessness and how they compare to the needs of older housed adults and younger adults experiencing homelessness. Where available, we include evidence on the differences between the subgroups of older adults experiencing homelessness for the first time compared to those who have previously experienced homelessness and between racial/ethnic groups that are disproportionately likely to experience homelessness.

Exhibit 2 provides a summary of the characteristics and service needs of older adults experiencing homelessness presented here in comparison to older housed adults and younger homeless adults.

Exhibit 2 Comparison of Characteristics and Needs of Older Adults Experiencing Homelessness

Older Adults Experiencing Homelessness | Finding | Compared to:
Older Adults Experiencing Homelessness | Finding | Older Housed Adults | Younger Adults Experiencing Homelessness
Physical Health Needs
Average life expectancy | 64-69 years | Shorter life expectancy | ---
Rates of health and geriatric conditions | 30-39% ADL impairment; 21-59% experience hypertension | Higher rates | Higher rates
Utilization of acute health care services | 43-70% have emergency department visits; 10-43% have hospitalizations | Higher utilization | Comparable rates
Behavioral Health Needs
Rates of mental health conditions | ~40% | Higher rates^1^ | No clear patterns^2^
Rates of substance use disorder | 26-63% | Higher rates | No clear patterns
Basic Needs
Rates of food insecurity | ~55% | Higher rates^3^ | Higher rates
Lack of transportation | --- | --- | ---

1 As compared to 3 nationally representative samples of older adults.

2 Indicates studies show inconsistent findings on the differences between older and younger adults experiencing homelessness.

3 As compared to national estimates of population living in poverty.

### Physical Health Needs

Older adults experiencing homelessness have significantly shorter life spans than housed older adults, though they die from similar chronic conditions.

Studies consistently document a shorter life span of older adults experiencing homelessness despite the range of sub-populations studied, including individuals staying in shelters in New York City (Metraux et al., 2011); veterans in transitional homeless programs (Schinka et al., 2017; Schinka & Byrne, 2018); and individuals experiencing homelessness in Oakland, California (Brown et al., 2016; Kushel, 2020). For example, Metraux and colleagues (2011) matched administrative records for adults staying in the New York City shelter system with death records from the Social Security Administration. They found that older adults experiencing homelessness have a life expectancy of approximately 64 years for men and 69 years for women (Metraux et al., 2011), compared to national life expectancies of 76 years for men and 81 years for women (Xu et al., 2020). Further, Hwang and colleagues (1997; 2008) found that both older adults experiencing chronic homelessness and those who first became homeless later in life had elevated mortality rates. Finally, although the most common causes of death among older homeless adults are similar to housed older adults, for example, cancer and cardiovascular disease, these illnesses occur approximately 20 years earlier (Kushel, 2020).

Older adults experiencing homelessness have health challenges similar to older adults who are housed but who are of more advanced ages.

Adults experiencing homelessness between ages 50 and 62 often have health conditions that are more severe than housed individuals their own age, but similar to those of housed people who are 10-20 years older (Cohen, 1999; Gelberg et al., 1990; HPRI, 2019; Brown et al., 2016). Compared to their housed counterparts, older adults experiencing homelessness have a higher prevalence and severity of physical and geriatric conditions including memory loss, falls, difficulty performing ADLs, and cognitive impairment (Brown et al., 2011; Brown et al., 2017; Hahn et al., 2006; Hwang et al., 1997). Moreover, comorbid conditions among older adults experiencing homelessness are common, including hypertension, arthritis, cognitive impairment, frailty, hearing difficulty, and urinary incontinence (Kushel, 2020; Brown et al., 2011, Brown et al., 2016; Brown, 2017; Gelberg et al., 1990). Additionally, in discussions, experts and providers noted that sleep deprivation resulting from sleeping in unsheltered locations such as tents or cars or in shelters that were crowded or offered limited hours of access exacerbated older adults’ physical and mental health challenges and accelerated cognitive decline.

Older adults have different health conditions than younger adults who are homeless, though adults of all ages experiencing homelessness have poorer health status than those who are housed.

Among those experiencing homelessness, older adults compared to younger adults have higher rates of chronic illnesses such as high blood pressure; geriatric conditions, including arthritis, and functional disability; and cognitive impairments (Garibaldi et al., 2005; Gelberg et al., 1990). To illustrate, in a cross-sectional, community-based survey of homeless adults in two United States cities, older adults were 3.6 times as likely to have a chronic medical condition as those under age 50 (Garibaldi et al., 2005). Older adults also were more likely to report two or more medical conditions (59 percent vs 28 percent) compared to the younger adults experiencing homelessness (Garibaldi et al., 2005). A five-year study of 28,000 adults who received care at the Boston Health Care for the Homeless Program reported death rates of almost 2.5 times higher for those ages 45-64 compared to those ages 25-44 (Baggett et al., 2013). When compared to the general housed population of the same ages, people 25-44 years old experiencing homelessness had mortality rates 9 times higher, while people 45-64 years old experiencing homelessness had mortality rates 4.5 times higher (Baggett et al., 2013).

Older adults experiencing homelessness utilize acute health care services at high rates and significantly more than the general population of older adults.

Older adults experiencing homelessness use acute health care services at high rates, with rates across studies ranging from 43 percent to 70 percent for emergency department visits and 10-43 percent for inpatient hospitalizations (Brown et al., 2010; Brown et al., 2011; Raven et al., 2017). Very few studies have compared national rates of acute health care services utilization between older adults experiencing homelessness to those of their housed counterparts. In a study comparing older adults experiencing homelessness in Boston to three nationally representative samples of older adults, 43 percent of the older homeless adults had been admitted to the hospital more than once in the prior year compared to 11 percent of the nationally representative sample. Moreover, whereas 70 percent of the older adults experiencing homelessness had more than one emergency department visit in the prior year, only 19 percent of the nationally representative sample of older adults did (Brown et al., 2011). Further, most older adults experiencing homelessness in the sample had received ambulatory care (87 percent) within the previous 12 months (Brown et al., 2011). A study using a similar sample of older adults experiencing homelessness found a small proportion of the sample accounted for half of all emergency departments and inpatient visits; those who spent the majority of the past six months homeless, either unsheltered or staying in shelters, had significantly higher rates of emergency department visits than those who had spent most of their time housed (Brown et al., 2010).

Older adults experiencing homelessness use the emergency department most frequently for injuries and exposure to violence; complications resulting from substance use, including alcohol and tobacco; and treatment of mental health disorders (Raven et al., 2017). Among people experiencing homelessness, emergency departments remain a low-barrier access point to seek pain management and medical treatment for chronic medical conditions and pain that could be managed in outpatient settings. Although over two-thirds of the sample of adults 50 and older experiencing homelessness in the study reported having a regular non-emergency place for routine care, it was not associated with reduced use of the emergency department (Raven et al., 2017).

Older adults and younger adults experiencing homelessness use acute health care services at similar rates, despite differences in having health insurance and a regular health care place or provider.

In Brown’s 2010 study of health care utilization by people experiencing homelessness, adults aged 50 and older were more likely to have health insurance, a regular place for health care, and a regular health care provider (e.g., medical doctor, nurse practitioner, or registered nurse) than those under 50. However, both groups had similar rates of acute health care utilization in the prior year, including emergency department visits (43 percent of older adults vs. 49 percent of younger adults) and inpatient hospitalizations (32 percent of older adults vs. 40 percent of younger adults) (Brown et al., 2010). This study showed no significant differences between age groups in the type of visit; most visits were for physical ailments (85 percent for older adults vs. 88 percent for younger adults) as opposed to emotional problems (19.5 percent for both age groups) (Brown et al., 2010).

### Behavioral Health Needs

Older adults experiencing homelessness, especially women, are more likely to have mental health conditions than older housed adults.

In studies with samples of older adults experiencing homelessness (Brown et al., 2011; Kaplan et al., 2019), older adults in permanent supportive housing (Henwood et al., 2018), and veterans (Schinka et al., 2012), between 40 percent and 58 percent either screened for or reported mental health conditions. For example, 56 percent of older adults in permanent supportive housing reported at least two chronic mental health conditions (Henwood et al., 2018). Depression was the most common condition identified; other conditions include schizophrenia and post-traumatic stress disorder. These rates of mental health conditions are higher among older adults experiencing homelessness than older housed adults (which range from 18 percent to 34 percent), measured both by diagnoses and symptomology (Brown et al., 2011; U.S. CDC, 2008).

Some studies find evidence of gender differences in rates of mental health conditions among older adults experiencing homelessness. Compared to older homeless men, older homeless women were two and one-half times more likely to have any chronic mental health condition and more likely to be diagnosed with more mental health conditions (Winetrobe et al., 2017; Dickins et al., 2021).

Findings from the Health and Retirement Study indicate race and ethnic differences in the behavioral health conditions of older adults experiencing homelessness. Compared to their White counterparts, Black and African American older adults experiencing homelessness are significantly more likely to report a history of illicit drug use and less likely to report a history of mental illness or domestic violence than White older adults experiencing homelessness (Chekuri et al., 2016).

Older adults experiencing homelessness also have more substance use disorders than the general population.

Although there are no studies that directly compare older homeless adults to their housed counterparts on substance use, a few studies have compared older homeless adults to population-based samples and to other samples. Studies generally find that a higher percentage of older adults experiencing homelessness report alcohol and/or drug use than population-based samples (e.g., CDC, 2008). In the HOPE HOME cohort of older adults experiencing homelessness, for example, rates of binge drinking were significantly higher in older homeless adults than in three large-scale studies of older adults using population-based samples (30 percent vs. 1 percent, 7 percent, and 3 percent) and a greater percentage of the older adults experiencing homelessness reported moderate or greater severity of alcohol use (26 percent) than housed adults of all ages (5 percent) served in a U.S. Department of Veterans Affairs (VA) primary care clinic (Brown et al., 2019). This sample also had a higher rate of current illicit substance use (63 percent) than a national community-based sample of adults of all ages experiencing homelessness (23 percent) (Spinelli et al., 2017).

“I’ve dealt with a lot of trauma as well. I lost my best friend that I’ve known since I was 17 years old due to COVID, so there you go again now. Setback is you start using again, just to numb the pain, you know what I mean?” – Male, 59

Studies to date yield inconsistent findings on the differences in mental health conditions and substance use between older and younger adults experiencing homelessness.

It is unclear whether there are age differences in the prevalence of behavioral health conditions among individuals experiencing homelessness. Whereas some studies have found a higher prevalence of mental health conditions such as anxiety, depression, and post-traumatic stress disorder (Garibaldi et al., 2005; Tompsett et al., 2009) among older adults experiencing homelessness than among their younger counterparts, other studies have found either no significant differences in the rates of these conditions (DeMallie et al., 1997; Gelberg et al., 1990) or the opposite finding (Gordon et al., 2012).

Similarly, the limited studies that contrast rates of substance use between older and younger adults experiencing homelessness yield mixed findings. Some studies suggest that, among people experiencing homelessness, younger adults are more likely to use drugs than older adults while older adults may be more likely to use alcohol (DeMallie et al., 1997; Gordon et al., 2012). Yet other studies fail to find such differences (Hecht & Coyle, 2001; Gelberg et al., 1990) or find that there is a lower prevalence of substance use disorders for older versus younger adults experiencing homelessness (Burt et al., 1999; Dietz et al., 2009).

Preliminary evidence suggests older adults who first experienced homelessness earlier in life are more likely to have behavioral health conditions than those who first experienced homelessness after age 50.

In the only study to compare differences between newly and chronically homeless older adults, Brown and colleagues (2016) found that participant characteristics and life course experiences differed by age at first homelessness. Compared to individuals whose first homelessness occurred at age 50 or older, individuals with first homelessness before age 50 showed a greater prevalence of behavioral health disorders at different stages in life. For example, this group had higher rates of drug use in childhood and mental health problems in young and middle adulthood, as well as a higher prevalence of current mental health issues, including depressive symptoms and post-traumatic stress disorder, and drug use, and higher rates of hospitalizations for mental health problems in adulthood (Brown et al., 2016).

“I mean, I’m going to be 60 years old. It’s getting cold out and… I’m not settled carrying a backpack around every freaking day. It’s like my back is starting to bother me. I got health issues. I only got one kidney that’s functioning 40% because I had cancer a little over a year ago. That’s the second time I had cancer in 6 years. So, it’s like, you know what? I need to be settled down in a place.” – Male, 59

Individuals who had experienced homelessness as older adults reported high rates of physical and behavioral health problems, echoing findings from the literature.

All of the older individuals with lived experience of homelessness with whom we spoke discussed suffering from physical and behavioral health problems, including diabetes, HIV, traumatic brain injury, glaucoma, arthritis, bipolar disorder, post-traumatic stress disorder, and substance use disorder. A few people also reported having experienced strokes or cancer in the past. Many of the interviewees, including all of those who were homeless at the time of our interview, reported physical pain and mobility issues, often attributed to being unsheltered. For example, one individual reported they had lost several toes due to frostbite contracted while being outside in bad weather.

### Basic Needs

Older adults experiencing homelessness have high rates of food insecurity.

Food insecurity coupled with insufficient nourishment complicates chronic disease management and presents a major challenge for older homeless adults who have a high prevalence of chronic disease and limited mobility (Brown et al., 2011; Patanwala et al., 2018). Food insufficiency among older adults is associated with significantly greater odds of hospitalization for any reason, psychiatric hospitalization, and high emergency department utilization (Baggett et al., 2011). Individuals who are food insecure -- having limited access to adequate food due to lack of resources -- have poorer health and are more likely to consume foods deficient in nutrients (Robaina & Martin, 2013). Also, severely cost-burdened older adults who are in the bottom income quartile reduce their spending on food by 30 percent more than those who are not cost-burdened (National Association of Area Agencies on Aging [n4a], n.d. b). Among participants in the HOPE HOME study, over half reported food insecurity, with one-third reporting low food security and one-quarter reporting very low food security (Tong et al., 2018), consistent with food insecurity estimates among other homeless populations (e.g., Parpouchi et al., 2016) and nearly two times higher than national estimates among the United States population living in poverty (Coleman-Jensen et al., 2016).

Lack of transportation poses a significant barrier for older adults experiencing homelessness.

Adults experiencing homelessness commonly indicate their most used modes of transportation include public transit and walking (Chan et al., 2014; North et al., 2017; Murphy, 2019), which are more difficult for older individuals with mobility challenges. Lack of transportation has been cited as a barrier for adults experiencing homelessness, as it reduces access to shelter and housing, medical and behavioral health care, social engagement, food, and other supportive services (Greysen et al., 2012; Hui & Habib, 2014, 2017; Niño, Loya, & Cuevas, 2009; Murphy, 2019; Turnbull, Muckle, & Masters, 2007). Among studies of older adults experiencing homelessness, mobility challenges (i.e., difficulty walking without help) and challenges with instrumental ADLs such as using public transportation are common (Henwood et al., 2018). Thus, it is reasonable to conclude that older adults experiencing homelessness face transportation barriers even beyond those of younger adults experiencing homelessness. However, there is little available research focused on transportation issues specifically among older adults experiencing homelessness.

Older adults experiencing homelessness, including those who are newly placed into housing, experience loss of community.

Many of the experts and providers with whom we spoke noted that mobility limitations, frequent address changes, receipt of housing assistance in a new neighborhood, and the death of family and friends contribute to formerly homeless older adults having limited social networks. Multiple interviewees noted that social and physical isolation among this population can contribute to further cognitive and physical declines. One housing provider noted that formerly homeless older residents in her organization’s properties often struggle to identify someone who can serve as their medical power of attorney following years of social isolation.

1 In its Annual Homelessness Assessment Reports to Congress, HUD publishes the percentage of people experiencing unsheltered homelessness only for three age groups: under 18, 18-24, and over 24. Data for older adults (55-64 and 65 and older) are only available for sheltered populations.

2 In HUD’s Annual Homelessness Assessment Reports to Congress, the age categories for older adults changed in 2017 from 51-62 and 62 and older to 55-64 and 65 and older in 2018. Thus, we cannot measure changes over time in the size of the population of older adults experiencing sheltered homelessness from before 2017 to present.