# Section 1 Introduction

The number of older adults living in poverty is increasing (Li & Dalaker, 2021) due in part to the aging of the United States population overall, coupled with the growing affordable housing crisis (Aurand et al., 2021) and the public health and economic crises that resulted from the Coronavirus Disease 19 (COVID-19) pandemic. Older adults are increasingly likely to be housing cost-burdened (i.e., housing costs require more than 30 percent of household income) and severely housing cost-burdened (i.e., housing costs require more than 50 percent of household income). In 2019, around 5 million households headed by someone aged 65 or older paid at least 30 percent of their income on rent, and another 5 million paid at least 50 percent (Joint Center for Housing Studies, 2019). Not surprisingly, the population of older adults at risk of or experiencing homelessness is also growing rapidly and is projected to continue to grow over the next decade (Culhane et al., 2013; Culhane et al., 2019). Until recently, older adults who experience homelessness have largely struggled with housing issues throughout much of their adult lives (Culhane et al., 2013), concomitant with other health and life challenges. Yet, recent research has identified a growing subgroup of older adults who become homeless for the first time after the age of 50, due largely to economic factors (Brown et al., 2016; Crane et al., 2005; Shinn et al., 2007).

Terminology

Throughout the report, we use the term “older” adults to refer to people 50 years of age and older, and the term “senior” to refer to people 62 years of age and older. We use the term “elderly” only when referring to specific eligibility criteria for the various programs and services discussed.

The growth in this population and the different pathways they follow into homelessness underscore the critical importance of understanding the needs of this vulnerable population and what services and housing can best address them. Drawing on published literature and interviews with researchers, providers, and people experiencing homelessness, this report provides an overview of the characteristics and needs of older adults at risk of or experiencing homelessness, differences between individuals who are newly experiencing homelessness in older age and those who first experienced homelessness earlier in life, and the types of services, housing, and supports needed to serve them. Using an equity lens, we examine these topics with attention to what is known about racial and ethnic groups disproportionately impacted by homelessness. Finally, we add to this summary an exploration of the programs, policies, services, and supports that exist to prevent and address homelessness across the systems that serve older adults. Brought together, the research and systems’ offerings provide a roadmap for determining what is available now to both prevent homelessness among those at risk as well as what is available to serve those who are experiencing homelessness. We highlight the challenges older adults face in accessing the assistance they need, innovative practices, especially those implemented during the COVID-19 pandemic that could ease these challenges, and remaining gaps that exist that need to be filled to effectively tackle the problem.

## OVERVIEW OF REPORT

Section 2 provides a discussion of the population of older adults experiencing homelessness, including the prevalence of and pathways into homelessness. We examine the characteristics and needs of older adults experiencing homelessness, including sociodemographic characteristics, health and behavioral health conditions, and basic needs. Where possible, we compare these characteristics and needs to those of housed older adults as well as to younger adults who are homeless to understand how the characteristics and needs of older adults experiencing homelessness may be unique. Section 3 addresses the systems and services available to serve older adults at risk of or experiencing homelessness, including homelessness and housing supports, health and behavioral health services, income supports, and other basic needs assistance programs. For each of these service areas, we describe the assistance available to low-income older adults generally and to older adults experiencing homelessness specifically. We highlight challenges older adults face in accessing assistance and innovative programs or strategies available to serve them. We also address changes in policies or practices during the COVID-19 pandemic to facilitate access to needed services for older adults experiencing homelessness may be beneficial to continue post-pandemic. In Section 4, we identify critical gaps in the housing and services available to meet the needs of older adults at risk of or experiencing homelessness and in existing research. We end with potential strategies to better identify and serve older adults at risk of or experiencing homelessness.

## METHODOLOGY

This report incorporates findings from an environmental scan, including a review and synthesis of published research, evaluations, and white papers, discussions with subject matter experts and housing and service providers, and interviews with people with lived experience of homelessness in older adulthood. Each of these methods is described in further detail in the Appendix. For the environmental scan, we used a systems approach for identifying key resources, including focused searches on literature and other resources within the fields of homelessness and housing, health and behavioral health, and aging. We also conducted discussions with a diverse set of subject matter experts and housing and service providers. Throughout the report, these individuals are referred to as experts and providers. We also collected data through tailored conversations from individuals between the ages of 56 and 74 who were experiencing or had experienced homelessness as older adults. Six people were currently experiencing homelessness at the time of the discussion and were staying in shelters, in tents, or on the sidewalk. Eight people were housed, with seven in permanent supportive housing and one in low-income housing. The goals of these conversations were to learn more about their experiences accessing the housing, supports they needed, and challenges they faced.