# Appendix Overview of Methodology

This report incorporates findings from an environmental scan, including a review and synthesis of published research, evaluations, and white papers; discussions with subject matter experts and housing and service providers; and conversations with people with lived experience of homelessness in older adulthood. Each of these methods is described in further detail below.

## ENVIRONMENTAL SCAN

We used a systems approach for identifying key resources, including focused searches on literature and other resources within the fields of homelessness and housing, health and behavioral health, and aging. We began the literature review with identification and review of the seminal articles on older adult homelessness (e.g., Brown et al., 2011, 2016; Brown et al., 2016; Culhane et al., 2013; Culhane et al., 2019; Kushel, 2020; Shinn et al., 2007) and the bibliographies of the leading scholars in the field to identify both published and unpublished relevant resources, including reports, evaluations, and datasets along with research articles. From this initial review, we developed a list of key words to use in a broader search, augmented with terms based on our knowledge of services and supports available across systems to serve older adults at risk of or experiencing homelessness.

Exhibit A-1 outlines the key words and search terms used.

Exhibit A-1 Key Words and Search Terms Used to Identify Relevant Published and Unpublished Literature

Population:; - Older adults; - Aging adults; - Seniors; - Elderly people; - Veterans | Conditions:; - Low-income; - Equity/discrimination; - Rent-burdened; - Unsheltered; - Food insecurity; - Uninsured/underinsured | Services:; - Homelessness prevention; - Outreach/engagement; - Crisis/interim housing; - Rapid re-housing; - Permanent supportive housing; - Affordable housing/lowincome housing; - Medicare/Medicaid; - Medical respite care; - Income supports (SSI/SSDI); - Food and nutrition assistance; - Transportation assistance | Systems:; - Homelessness; - Housing; - Health care; - Behavioral health; - Social services; - Aging services; - VA

The sources searched for relevant literature are detailed in Exhibit A-2.

We conducted a series of systematic searches using the key words to identify the population of interest in combination with conditions, services, and systems. For example, searches included “older adults” combined with “low-income”, “homelessness prevention”, “homelessness services”, and so on. Using these combinations of terms, we searched a variety of databases of published literature to identify research on characteristics, service needs, and interventions for older adults experiencing homelessness. We also searched government agency websites for information about eligibility and coverage of services and supports across a range of systems. Next, we searched the websites of research organizations, service providers, and advocacy organizations for additional information about the needs of older adults at risk of or experiencing homelessness, the challenges they face in accessing assistance, and specific programs that are working to address these challenges. Finally, we identified additional studies and reports recommended by experts and providers during the interview phase of the project. This process identified 364 potential sources.

Exhibit A-2 Sources Searched to Identify Relevant Published and Unpublished Literature

- Seminal articles in field; - Bibliographies of leading scholars; - Databases of published literature (PsycINFO, ProQuest, SAGE Research Methods, FirstSearch, PubMed, LitCovid); - Government agencies; – Administration for Community Living/Administration on Aging; – Centers for Disease Control and Prevention; – Centers for Medicare & Medicaid Services; – Substance Abuse and Mental Health Services Administration; – U.S. Department of Health and Human Services; – U.S. Department of Housing and Urban Development; – U.S. Department of Veterans Affairs; – U.S. Interagency Council on Homelessness; – U.S. Social Security Administration; - Research, service, and advocacy organizations; – AmeriCorps; – Assisted Living Org; – Association of Mature American Citizens Foundation; – Benioff Homelessness and Housing Initiative; – Center for Housing Policy; – Center on Budget and Policy Priorities; – Corporation for Supportive Housing; – Council of Large Public Housing Authorities; – Homelessness Policy Research Institute; – Joint Center for Housing Studies, Harvard University; – Abdul Latif Jameel Poverty Action Lab Justice in Aging; – LeadingAge; – National Adult Protective Services Association; – National Adult Protective Services Resource Center; – National Alliance to End Homelessness; – National Association of Area Agencies on Aging; – National Coalition for the Homeless; – National Council on Aging; – National Health Care for the Homeless Council; – National Low Income Housing Coalition; – USAging

Once materials were collected, we applied a protocol to appraise the resources for factors that may influence their interpretation and prioritization. For example, for studies on the characteristics of the population, we considered the study location, the population included, and the year of completion. Studies that occurred fully outside of the United States or Canada were excluded from consideration. For studies on samples that were small or not representative of all older adults experiencing homelessness (e.g., individuals living in a particular city or individuals recruited from drop-in centers), we integrated details of the studies that may influence their generalizability (such as sampling strategy or geographic location) into the summary of findings to provide appropriate context for the reader. For literature on program resources and interventions, we prioritized the most current information available. In the final scan, we incorporated 164 of the materials identified.

Compared to the larger literature on homelessness among all populations, only a few studies have focused specifically on older homeless adults, and most of these studies have been conducted within the last decade. Several of the studies reviewed in this report are based on small samples concentrated in urban areas. These limited samples pose challenges in drawing generalizations about older adults’ experiences with homelessness and the supports available for them. Thus, the picture presented here, though illustrative, may not include the experiences of all older adults, such as those from rural areas. The examination of demographic composition of the population of older adults experiencing homelessness is especially new; only a few studies exist examining differences in the needs and trajectories between subgroups of older adults or the influence of characteristics such as race and ethnicity and immigration status.

Several articles reviewed in this report originate from a single cohort of older adults who participated in the landmark HOPE HOME study (Brown et al., 2011, 2016; Hurstak et al., 2017; Kaplan et al., 2019; Kushel, 2020; Lee et al., 2016; Raven et al., 2017). This study followed a cohort of 350 older adults experiencing homelessness in Oakland, California over three years. The study used clinical assessments and structured interviews to assess geriatric conditions (functional, cognitive, and sensory impairment), housing history, behavioral health (mental health and alcohol and substance use disorders), physical health (chronic diseases), and acute health care utilization (emergency department visits, inpatient hospitalizations, and skilled nursing facility placement). As the first study of its kind to focus on this population, it provides much-needed data on the experiences, trajectories, and consequences of geriatric conditions in homeless adults aged 50 and older, providing important insights into the type of housing and services that may be effective for serving this population. Yet there remains a need for additional research to replicate this study to build on these learnings and assess the generalizability of the findings for all older adults experiencing homelessness.

## DISCUSSIONS

### Discussions with Subject Matter Experts and Providers

Between June and October 2022, we conducted a series of discussions with a diverse set of subject matter experts and housing and service providers on homelessness among older adults.

Nine subject matter experts representing different disciplines of research, policy, practice, and systems with expertise in aging and homelessness were selected, including those with expertise in population changes, behavioral health, housing, prevention, health care/long-term care, veteran populations, aging services, and racial equity. We also selected representatives from eight housing and service provider agencies located throughout the country, including providers of homelessness prevention, outreach, and drop-in assistance; health care and respite care; permanent supportive housing, and aging support services. Throughout the report, we refer to these individuals as experts and providers, respectively.

These expert and provider discussions supplemented information learned through the literature review. The discussions followed a semi-structured format and focused on providing a deeper understanding of:

- The characteristics and needs of older adults at risk of or experiencing homelessness.
- Challenges to and potential strategies for identifying older adults in need and engaging them in assistance.
- The range of services and supports across service sectors that are available to meet their needs, including innovative interventions to explore.
- Gaps in services and supports that remain.
- Barriers and facilitators of cross-system coordination.
- Areas for which additional research is needed.

### Discussions with People Experiencing Homelessness

We collected data through tailored conversations from individuals between the ages of 56 and 74 who were experiencing or had experienced homelessness as older adults. All but one of the individuals were recruited for participation through three provider agencies -- two permanent supportive housing programs for older adults located in the northeast and one drop-in center for older adults located in the southwest. The final individual was identified through her work as a national mental health consumer advocate and policy consultant who has written a personal account of the challenges of experiencing homelessness as an older adult. Six people were currently experiencing homelessness at the time of the discussion, staying in shelter, in tents, or on the street. Eight people were housed, with seven in permanent supportive housing and one in low-income housing. The goals of these conversations were to learn more about their experiences accessing the housing and supports they needed and the challenges they faced Westat staff conducted six of these conversations, while the remaining eight conversations were led by case managers from the participating agencies using protocols developed by Westat.