# REFERENCES

Abramson E.L., Edwards A., Silver M., & Kaushai R. (2014). Trending health information technology adoption among New York nursing homes. American Journal of Managed Care, 20(11 Spec No. 17), eSP53–59.25811820
Alexander G.L., Steege L.M., Pasupathy K.S., & Wise K. (2015). Case studies of IT sophistication in nursing homes: a mixed method approach to examine communication strategies about pressure ulcer prevention practices. International Journal of Industrial Ergonomics, 49, 156–166.
Alvarado C.S., Zook K., & Henry J. (2017). Electronic Health Record Adoption and Interoperability among US Skilled Nursing Facilities in 2016. ONC Data Brief. https://dashboard.healthit.gov/evaluations/data-briefs/electronic-health-record-adoption-interoperability-nursing-facilities-2016.php#:~:text=In%202016%2C%2064%25%20of%20SNFs,location%2C%20nor%20by%20bed%20size.
Andersen L.E., Tripp L., Perz J.F., Stone N.D., Viall A.H., Ling S.M., & Fleisher L.A. (2021). Protecting nursing home residents from COVID-19: federal strike team findings and lessons learned. NEJM Catalyst Innovations in Care Delivery. https://catalyst.nejm.org/doi/full/10.1056/CAT.21.0144.
Bailey V. (2021). Skilled nursing facilities had mixed reviews of telehealth use. MHealthIntelligence. https://mhealthintelligence.com/news/skilled-nursing-facilities-had-mixed-reviews-of-telehealth-use.
Bercovitz A., Sengupta M., & Jamison P. (2010). Electronic Medical Record Adoption and Use in Home Health and Hospice. NCHS Data Brief, no 45.
Bercovitz A.R., Park-Lee E., & Jamoom E. (2013). Adoption and use of electronic health records and mobile technology by home health and hospice care agencies. National Health Statistics Report, (66), 1–11.
Caffrey C., Cairns C., & Rome V. (2020). Trends in Electronic Health Record Use among Residential Care Communities: United States, 2012, 2014, and 2016. National Health Statistics Reports, no 140. https://www.cdc.gov/nchs/data/nhsr/nhsr140-508.pdf.
CareQuality. (n.d.). Home Page. Retrieved February 3, 2022, from https://carequality.org/.
Dougherty M., Williams M., Millenson M., & Harvell J. (2013). EHR Payment Incentives for Providers Ineligible for Payment Incentives and Other Funding Study. https://aspe.hhs.gov/basic-report/ehr-payment-incentives-providers-ineligible-payment-incentives-and-other-funding-study.
Felix H., Dayama N., Morris M.E., Pradhan R., & Bradway C. (2021). Organizational characteristics and the adoption of electronic health records among nursing homes in one southern state. Journal of Applied Gerontology, 40(5), 481–488. 10.1177/0733464820906685.32081058
Henry J., Pylypchuk Y., & Patel V. (2018). Electronic Health Record Adoption and Interoperability among US Skilled Nursing Facilities and Home Health Agencies in 2017. ONC Data Brief. https://www.healthit.gov/sites/default/files/page/2018-11/Electronic-Health-Record-Adoption-and-Interoperability-among-U.S.-Skilled-Nursing-Facilities-and-Home-Health-Agencies-in-2017.pdf.
Henry J., Pylypchuk Y., Searcy T., & Patel V. (2016). Adoption of Electronic Health Record Systems among U.S. Non-Federal Acute Care Hospitals: 2008–2015. https://www.healthit.gov/sites/default/files/briefs/2015_hospital_adoption_db_v17.pdf.
HL7 FHIR Exchange Network. (n.d.). FHIR Exchange Module. Retrieved February 3, 2022, http://www.hl7.org/fhir/exchange-module.html.
Kaiser Family Foundation (KFF). (2022). State COVID-19 Data and Policy Actions. Retrieved February 3, 2022, https://www.kff.org/coronavirus-COVID-19/issue-brief/state-COVID-19-data-and-policy-actions/#long-term-care-cases-deaths.
LeadingAge. (2015). Electronic Health Record Adoption and Health Information Exchange among Long Term and Post Acute Care Providers: A Survey of LeadingAge New York Members. http://www.leadingageny.org/?LinkServID=2E102FA3-007E-0553-F50E1E2BB975E3DC.
LeadingAge Center for Aging Services Technology. (2021). Technology Selection Tools. https://leadingage.org/technology-selection-tools?_ga=2.69199569.1524041378.1628129418-1365451774.1616156820.
Office of the National Coordinator for Healthcare Technology (ONC). (2019). Office-based Physician Electronic Health Record Adoption. Retrieved July 26, 2021, https://dashboard.healthit.gov/quickstats/pages/physician-ehr-adoption-trends.php.
Powell K.R., & Alexander G.L. (2021). Consequences of rapid telehealth expansion in nursing homes: Promise and pitfalls. Applied Clinical Informatics, 12(4), 933–943. 10.1055/s-0041-1735974.34614517
Richard A., Kaehny M., May K., & Kramer A. (2008). Literature Review and Synthesis: Existing Surveys on Health Information Technology, including Surveys on Health Information Technology in Nursing Homes and Home Health. https://aspe.hhs.gov/sites/default/files/private/pdf/75641/HITlitrev.pdf.
Samson L., Tarazi W., Turrini G., & Sheingold S. (2021). Medicare Beneficiaries’ Use of Telehealth Services in 2020--Trends by Beneficiary Characteristics and Location. Issue Brief No. HP-2021– 27. https://www.aspe.hhs.gov/sites/default/files/documents/a1d5d810fe3433e18b192be42dbf2351/medicare-telehealth-report.pdf?_ga=2.234995651.313728446.1638808754-1494035394.1632321790.
Shea C.M., & Belden C.M. (2016). What is the extent of research on the characteristics, behaviors, and impacts of health information technology champions? A scoping review. BMC Med Inform Decis Mak, 16:2. doi: 10.1186/s12911-016-0240-4. PMID: 26754739; PMCID: PMC4709871.26754739
Schreiber M., Holland E. Andress J., & Wickiser L. (2021). Advancing Digital Strategies for Quality Measurement and Improved Care. 2021 CMS Quality Conference.
Vest J.R., Jung H.Y., Wiley K. Jr., Kooreman H., Pettit L., & Unruh M.A. (2019). Adoption of health information technology among US nursing facilities. Journal of the American Medical Directors Association, 20(8), 995–1000.e1004. 10.1016/j.jamda.2018.11.002.30579920
White House. (2021). Executive Order on Protecting Public Health and the Environment and Restoring Science to Tackle the Climate Crisis. https://www.whitehouse.gov/briefing-room/presidential-actions/2021/01/20/executive-order-protecting-public-health-and-environment-and-restoring-science-to-tackle-climate-crisis/.
Wicklund E. (2021). Is the time right for skilled nursing facilities to embrace telehealth? MHealthIntelligence. https://mhealthintelligence.com/news/is-the-time-right-for-skilled-nursing-facilities-to-embrace-telehealth.
Wolf L., Harvell J., & Jha A.K. (2012). Hospitals ineligible for federal meaningful-use incentives have dismally low rates of adoption of electronic health records. Health Affairs, 31(3), 505–513. 10.1377/hlthaff.2011.0351.22392661