# EXECUTIVE SUMMARY

Background: The United States health care system is progressing incrementally toward an electronically connected ecosystem with the goals of delivering high-quality health care, lowering costs, and enabling digital health. To achieve interconnectedness, some providers were eligible to adopt certified electronic health record (EHR) technology. Progress continues for these providers as programs, requirements, and standards are evolving in a coordinated way to advance interoperability. Other providers including long-term and post-acute care (LTPAC) were not targeted to adopt interoperable health information technology (HIT) in a similar manner as their care partners in hospitals and physician-offices. The industry is relying instead on market forces to drive interoperability in LTPAC. Lessons from the COVID-19 pandemic are highlighting the challenges of this approach and the need for seamless interconnectivity not only between hospitals and physician-offices, but also with public health entities and LTPAC. This study aimed to understand the latest information available on the LTPAC sector’s adoption and use of HIT and health information exchange (HIE) including the barriers, facilitators, and policy levers.

Adoption: Findings gathered through an environmental scan and subject matter expert (SME) interviews show that LTPAC providers are adopting EHRs (80% for nursing homes and home health) with many similar features to certified HIT requirements, but they lack alignment with standards and use cases to support interoperable HIE. There are champions in LTPAC using HIT in innovative ways. However, most LTPAC providers struggle to prioritize EHR optimization and few have the resources (financial and workforce) to change clinical and administrative workflows that better use interoperability features available to them.

Barriers and Facilitators: This study, consisting of an environmental scan and SME interviews, found consistent themes regarding barriers and facilitators. We found little evidence of programs that effectively promote the widespread use of HIE by LTPAC in the same way that the Meaningful Use/Promoting Interoperability Program were effective for hospitals and physician-office settings. Lack of alignment with these programs or equivalent policy levers could further widen the gap between LTPAC and their care partners. Some existing barriers and facilitators are unique to specific key users such as providers, vendors, policy makers, payers, and public health experts.

Study Findings

- LTPAC providers are adopting EHRs to support their clinical and business needs (80% for nursing homes and home health) but interoperable exchange of health information is not routine or widely used.
- Data is needed from LTPAC organizations by others but LTPAC providers lack monetary incentives, policy requirements, or a strong business case to increase interoperability.
- LTPAC use of interoperability features available in their EHRs lags without a driver or policy lever.
- Many LTPAC providers struggle to prioritize EHR optimization and few have available resources for training and workflow changes.
- Innovators in LTPAC HIT are focusing on telehealth, remote patient monitoring, medication management, functional assessment and activity monitoring, shared care planning, social connectedness and engagement, safety, and data analytics.
- There are opportunities for emerging policies to support interoperability in LTPAC.

Use of HIT and HIE for Care Coordination and Reporting: LTPAC EHRs have functionality to support their specific clinical, care coordination, and reporting needs but lack alignment with the standards and requirements used by hospitals and physician-offices. For clinical care, system functionality includes demographics, problem lists, vital signs, computerized physician order entry, medication lists, electronic notes, assessments, reporting, and more (described further in Appendix C). While these features may be available to LTPAC providers, the extent of their use varies widely. Health information is regularly exchanged between LTPAC and their care partners to support transition of care, care coordination during a stay, and for administrative purposes (quality reporting, public health reporting, payment, and oversight). Few interoperable solutions are deployed to support the exchange. For care coordination, work around processes are established rather than interoperable solutions. Today’s reporting systems for quality measurement and public health reporting include electronic exchange of data, but do not use interoperable standards and data to do so.

Policy Considerations: Based on the environmental scan findings and SME interviews, the following policy considerations and approaches were identified to advance interoperable EHR adoption and use in LTPAC:

- Understand and address the barriers that limit policy makers from including LTPAC in HIT and interoperability programs including statutory limitations to include LTPAC in HIT policies and regulations.
- Spur adoption of interoperable HIT in LTPAC settings by considering policy options to increase adoption. Understand the effectiveness of past policies, funding, and interventions and look at future program changes to support LTPAC interoperability such as with digital quality measures (dQMs) and reporting, public health reporting modernization, and targeted payer process such as pre-claim review and prior authorization programs.
- Improve HIE across platforms, networks, and geographies by understanding the value proposition for LTPAC to participate in HIEs/health information networks (HINs), improving the ease of data sharing, and clarifying HIE/HIN vendor and provider relationships.
- Investigate telehealth policy, planning, use, and research in LTPAC, including barriers, facilitators, policies, reimbursement, and technology readiness for greater telehealth adoption in LTPAC settings.