# Acronyms

The following acronyms are mentioned in this report and/or appendices.

ASPE: Office of the Assistant Secretary for Planning and Evaluation
CDC: Centers for Disease Control and Prevention
CDS: Clinical Decision Support
CEHRT: Certified Electronic Health Record Technology
CMS: Centers for Medicare & Medicaid Services
COVID-19: Novel Coronavirus
CPOE: Computerized Provider Order Entry
CQM: Clinical Quality Measure
DEL: Data Element Library
dQM: Digital Quality Measure
EHR: Electronic Health Record
FHIR: Fast Healthcare Interoperability Resources
HHA: Home Health Agency
HIE: Health Information Exchange
HIN: Health Information Network
HIT: Health Information Technology
HL7: Health Level Seven
IRF: Inpatient Rehabilitation Facility
KFF: Kaiser Family Foundation
LTCH: Long-Term Care Hospital
LTPAC: Long-Term and Post-Acute Care
NCHS: National Center for Health Statistics
NF: Nursing Facility
NH: Nursing Home
NHSN: National Healthcare Safety Network
ONC: Office of the National Coordinator for Healthcare Technology
PACE: Program of All-inclusive Care for the Elderly
PACIO: Post-Acute Care Interoperability project
SME: Subject Matter Expert
SNF: Skilled Nursing Facility
USCDI: U.S. Core Data for Interoperability