# SECTION 7 CONCLUSION

While LTPAC providers are adopting EHRs, the lack of alignment of systems and standards to support interoperability with their clinical partners continues to be a challenge. Across all levels of the LTPAC space, from providers to HIN/HIEs, government entities to public health entities, there are differing interpretations of needs and reasons for lagging adoption and use of interoperable EHRs. Through an environmental scan and SME interviews, we identified potential policy considerations to help bridge the gaps. This report serves to broaden the understanding of the evolving ecosystem and to illustrate that there is no singular driver of changes in the LTPAC sector. Although consistent themes emerged on barriers and facilitators across the industry, there exist barriers and facilitators that are unique to specific key users such as payers and public health reporting. Policy levers such as incentives and requirements have resulted in widespread adoption of EHRs for hospitals and physician-offices providing the foundation for incremental progress toward interoperability in a coordinated way. This progress alone has not provided enough market force for LTPAC to adopt interoperable solutions. The COVID-19 pandemic has highlighted the need for seamless exchange mechanisms between hospitals, physicians, and LTPAC providers, and prioritizing public health reporting in policy would be an opportunity to leverage and build HIE/HIN adoption.